# Appendixes

Appendix A. Search Strategies

Appendix B. Inclusion and Exclusion Criteria

Appendix C. U.S. Preventive Services Task Force Quality Rating Criteria

Appendix D. Criteria for Assessing Scientific Quality of Systematic Evidence Reviews

Appendix E. Quality of Prognosis Studies Criteria

Appendix G. Excluded Studies