# Appendix G. Excluded Studies

## Reference

1 Ahmadi J. A controlled trial of buprenorphine treatment for opium dependence: the first experience from Iran. Drug & Alcohol Dependence. 2002;66(2):111-4. Excluded for quality. [pmid: 11906798].
2 Ahmadi J. Methadone versus buprenorphine maintenance for the treatment of heroin-dependent outpatients. 2003. Comparative effectiveness
3 Akerele EO BL. Treatment of cocaine/marijuana abuse among schizophrenic individuals: a look at the efficacy of the atypical neuroleptics. 14th Annual Scientific Meeting of 2006. Comparative effectiveness
4 Amass L. Thrice-weekly supervised dosing with the combination buprenorphine-naloxone tablet is preferred to daily supervised dosing by opioid-dependent humans. Drug & Alcohol Dependence 1961;(2). Comparative effectiveness
5 Amato L, Davoli M, Ferri M, Gowing L, Perucci CA. Effectiveness of interventions on opiate withdrawal treatment: an overview of systematic reviews. Drug & Alcohol Dependence. 2004;73(3):219-226. Does not report designated outcomes. [pmid: 15036544].
6 Amato L, Davoli M, Perucci A, Ferri M, Faggiano F, Mattick P. An overview of systematic reviews of the effectiveness of opiate maintenance therapies: available evidence to inform clinical practice and research. Journal of Substance Abuse Treatment. 2005;28(4):321-329. Excluded study design. [pmid: 15925266].
7 Amato L, Minozzi S, Davoli M, Vecchi S, Ferri M, Mayet S. Psychosocial combined with agonist maintenance treatments versus agonist maintenance treatments alone for treatment of opioid dependence. Cochrane Database of Systematic Reviews 2005;(4). Comparative effectiveness
8 American Psychiatric Association. Diagnostic and statistical manual of mental disorders, fourth edition, text revision. 4 ed. Washington DC.: American Psychiatric Association, 2000. Exclude, kept for background
9 Anderson F, Paluzzi P, Lee J, Huggins G, Svikis D. Illicit use of clonidine in opiate-abusing pregnant women. Obstetrics & Gynecology. 1997;90(5):790-794. Comparative effectiveness. [pmid: 9351766].
10 Appleby L, Dyson V, Luchins DJ, Cohen LS. The impact of substance use screening on a public psychiatric inpatient population. Psychiatric Services. 1997;48(10):1311-1316. Does not report designated outcomes. [pmid: 9323751].
11 Armstrong MA, Gonzales OV, Lieberman L, Carpenter DM, Pantoja PM, Escobar GJ. Perinatal substance abuse intervention in obstetric clinics decreases adverse neonatal outcomes. Journal of Perinatology. 2003;23(1):3-9. Does not evaluate appropriate intervention. [pmid: 12556919].
12 Ashley OS, Marsden ME, Brady TM. Effectiveness of substance abuse treatment programming for women: a review. American Journal of Drug & Alcohol Abuse. 2003;29(1):19-53. Exclude, kept for background. [pmid: 12731680].
13 Avants SK, Margolin A, Chang P, Kosten TR, Birch S. Acupuncture for the treatment of cocaine addiction. Investigation of a needle puncture control. J Subst Abuse Treat. 1995;12(3):195-205. Excluded population. [pmid: 7474027].
14 Baker A, Kochan N, Dixon J, Heather N, Wodak A. Controlled evaluation of a brief intervention for HIV prevention among injecting drug users not in treatment. AIDS Care. 1994;6(5):559-570. Does not evaluate appropriate intervention. [pmid: 7711089].
15 Baker A, Lee NK, Claire M, Lewin TJ, Grant T, Pohlman S, et al. Brief cognitive behavioural interventions for regular amphetamine users: a step in the right direction. Addiction. 2005;100(3):367-378. Comparative effectiveness. [pmid: 15733250].
16 Baker A, Lewin T, Reichler H, Clancy R, Carr V, Garrett R, et al. Evaluation of a motivational interview for substance use within psychiatric in-patient services. Addiction. 2002;97(10):1329-37. Excluded population. [pmid: 12359037].
17 Bale RN, Van Stone WW, Kuldau JM, Engelsing TM, Elashoff RM, Zarcone VP Jr. Therapeutic communities vs methadone maintenance. A prospective controlled study of narcotic addiction treatment: design and one-year follow-up. Arch Gen Psychiatry. 1980;37(2):179-193. Comparative effectiveness. [pmid: 7352849].
18 Barnett PG, Hui SS. The cost-effectiveness of methadone maintenance. Mt Sinai J Med. 2000;67(56):365-374. Exclude, kept for background. [pmid: 11064486].
19 Barnett PG, Rodgers JH, Bloch DA. A meta-analysis comparing buprenorphine to methadone for treatment of opiate dependence. Addiction. 2001;96(5):683-690. Comparative effectiveness. [pmid: 11331027].
20 Bastiaens L, Francis G, Lewis K. The RAFFT as a screening tool for adolescent substance use disorders. Am J Addict. 2000;9(1):10-16. Does not report designated outcomes. [pmid: 10914289].
21 Batki SL, Gruber VA, Bradley JM, Bradley M, Delucchi K. A controlled trial of methadone treatment combined with directly observed isoniazid for tuberculosis prevention in injection drug users. Drug & Alcohol Dependence. 2002;66(3):283-93. Comparative effectiveness. [pmid: 12062463].
22 Bergin C, Cameron CE, Fleitz RS, Patel AV. Measuring prenatal drug exposure. Journal of Pediatric Nursing. 2001;16(4):245-55. Does not evaluate appropriate intervention. [pmid: 11498817].
23 Berglund M. A better widget? Three lessons for improving addiction treatment from a meta-analytical study. Addiction. 2005;100(6):742-750. Excluded study design. [pmid: 15918803].
24 Bergmann PE, Smith MB, Hoffmann NG. Adolescent treatment. Implications for assessment, practice guidelines, and outcome management. Pediatr Clin North Am. 1995;42(2):453-472. Excluded study design. [pmid: 7724269].
25 Beswick T, Best D, Bearn J, Gossop M, Rees S, Strang J. The effectiveness of combined naloxone/lofexidine in opiate detoxification: results from a double-blind randomized and placebo-controlled trial. American Journal on Addictions. 2003;12(4):295-305. Sep. Comparative effectiveness. [pmid: 14504022].
26 Bibb KW, Stewart DL, Walker JR, Cook VD, Wagener RE. Drug screening in newborns and mothers using meconium samples, paired urine samples, and interviews. Journal of Perinatology. 1995;15(3):199-202. Comparative effectiveness. [pmid: 7666268].
27 Bisaga A, Aharonovich E, Garawi F, Levin FR, Rubin E, Raby WN et al. A randomized placebo-controlled trial of gabapentin for cocaine dependence. 2006. Comparative effectiveness
28 Botvin GJ, Baker E, Dusenbury L, Botvin EM, Diaz T. Long-term follow-up results of a randomized drug abuse prevention trial in a white middle-class population. JAMA. 1995;273(14):1106-1112. Excluded setting. [pmid: 7707598].
29 Botvin GJ, Botvin EM. School-based and community based prevention approaches. Substance abuse: A comprehensive textbook. 1995: 910–927. Excluded study design
30 Bovasso G. The long-term treatment outcomes of depression and anxiety comorbid with substance abuse. Journal of Behavioral Health Services & Research. 2001;28(1):42-57. Does not evaluate appropriate intervention. [pmid: 11329998].
31 Brady KT, Sonne SC, Malcolm RJ, Randall CL, Dansky BS, Simpson K, et al. Carbamazepine in the treatment of cocaine dependence: subtyping by affective disorder. Experimental & Clinical Psychopharmacology. 2002;10(3):276-85. Excluded for quality. [pmid: 12233988].
32 Breslin C, Li S, Sdao-Jarvie K, Tupker E, Ittig-Deland V. Brief treatment for young substance abusers: a pilot study in an addiction treatment setting. Psychology of Addictive Behaviors. 2002;16(1):10-6. Excluded for quality. [pmid: 11934080].
33 Brodie JD, Figueroa E, Dewey SL. Treating cocaine addiction: from preclinical to clinical trial experience with gamma-vinyl GABA. Synapse. 2003;50(3):261-265. Excluded for quality. [pmid: 14515344].
34 Brook JS, Finch SJ, Whiteman M, Brook DW. Drug use and neurobehavioral, respiratory, and cognitive problems: precursors and mediators. J Adolesc Health. 2002;30(6):433-441. Does not evaluate appropriate intervention. [pmid: 12039513].
35 Brown RL, Leonard T, Saunders LA, Papasouliotis O. A two-item screening test for alcohol and other drug problems.[see comment]. Journal of Family Practice. 1997;44(2):151-160. Exclude, kept for background. [pmid: 9040518].
36 Buhler KE. Euphoria, ecstacy, inebriation, abuse, dependence, and addiction: a conceptual analysis. Medicine, Health Care & Philosophy. 2005;8(1):79-87. Exclude, kept for background.
37 Calsyn DA, Wells EA, Fleming C, Saxon AJ. Changes in Millon Clinical Multiaxial Inventory scores among opiate addicts as a function of retention in methadone maintenance treatment and recent drug use. American Journal of Drug & Alcohol Abuse. 2000;26(2):297-309. Excluded for quality. [pmid: 10852362].
38 Campbell J, Nickel EJ, Penick EC, Wallace D, Gabrielli WF, Rowe C, et al. Comparison of desipramine or carbamazepine to placebo for crack cocaine-dependent patients. American Journal on Addictions. 2003;12(2):122-36. Apr. Comparative effectiveness. [pmid: 12746087].
39 Caplehorn JR, Dalton MS, Cluff MC, Petrenas AM. Retention in methadone maintenance and heroin addicts' risk of death. Addiction. 1994;89(2):203-209. Does not evaluate appropriate intervention. [pmid: 8173486].
40 Caplehorn JR, Dalton MS, Haldar F, Petrenas AM, Nisbet JG. Methadone maintenance and addicts' risk of fatal heroin overdose. Substance Use & Misuse. 1996;31(2):177-196. Does not evaluate appropriate intervention. [pmid: 8834006].
41 Carballo-Dieguez A, Sahs J, Goetz R, el Sadr W, Sorell S, Gorman J. The effect of methadone on immunological parameters among HIV-positive and HIV-negative drug users. Am J Drug Alcohol Abuse. 1994;20(3):317-329. Excluded study design. [pmid: 7977217].
42 Carey KB, Carey MP, Chandra PS. Psychometric evaluation of the alcohol use disorders identification test and short drug abuse screening test with psychiatric patients in India. J Clin Psychiatry. 2003;64(7):767-774. Excluded study design. [pmid: 12934976].
43 Carey KB, Cocco KM, Simons JS. Concurrent validity of clinicians' ratings of substance abuse among psychiatric outpatients. Psychiatric Services. 1996;47(8):842-847. Comparative effectiveness. [pmid: 8837156].
44 Carroll KM, Ball SA, Nich C, Martino S, Frankforter TL, Farentinos C et al. Motivational interviewing to improve treatment engagement and outcome in individuals seeking treatment for substance abuse: A multisite effectiveness study. 2006. Comparative effectiveness
45 Carroll KM, Ball SA, Nich C, O'Connor PG, Eagan DA, Frankforter TL, et al. Targeting behavioral therapies to enhance naltrexone treatment of opioid dependence: efficacy of contingency management and significant other involvement. Archives of General Psychiatry. 2001;58(8):755-61. Comparative effectiveness. [pmid: 11483141].
46 Carroll KM, Fenton LR, Ball SA, Nich C, Frankforter TL, Shi J, et al. Efficacy of disulfiram and cognitive behavior therapy in cocaine-dependent outpatients: a randomized placebo-controlled trial. Archives of General Psychiatry. 2004;61(3):264-72. Comparative effectiveness. [pmid: 14993114].
47 Carroll KM, Sinha R, Nich C, Babuscio T, Rounsaville BJ. Contingency management to enhance naltrexone treatment of opioid dependence: a randomized clinical trial of reinforcement magnitude. Experimental & Clinical Psychopharmacology. 2002;10(1):54-63. Comparative effectiveness. [pmid: 11866252].
48 Casanova OQ, Lombardero N, Behnke M, Eyler FD, Conlon M, Bertholf RL. Detection of cocaine exposure in the neonate. Analyses of urine, meconium, and amniotic fluid from mothers and infants exposed to cocaine. Archives of Pathology & Laboratory Medicine. 1994;118(10):988-93. Does not report designated outcomes. [pmid: 7944901].
49 Cavacuiti C, Selby P. Managing opioid dependence. Comparing buprenorphine with methadone. Canadian Family Physician. 2003;49:876-7. Comparative effectiveness. [pmid: 12901482].
50 Center for Substance Abuse Treatment. Clinical Guidelines for the Use of Buprenorphine in the Treatment of Opioid Addiction. TIP Series 40;DHHS Publication No. (SMA) 04-3939. 2004. Rockville, MD, Substance Abuse and Mental Health Services Administration. Treatment Improvement Protocol. Exclude, kept for background
51 Chaisson RE, Bacchetti P, Osmond D, Brodie B, Sande MA, Moss AR. Cocaine use and HIV infection in intravenous drug users in San Francisco. JAMA. 1989;261(4):561-565. Excluded study design. [pmid: 2909798].
52 Chang G, McNamara TK, Orav EJ, Koby D, Lavigne A, Ludman B, et al. Brief intervention for prenatal alcohol use: a randomized trial. Obstet Gynecol. 2005;105(5 Pt 1):991-998. Does not evaluate appropriate intervention. [pmid: 15863535].
53 Chang G, Wilkins-Haug L, Berman S, Goetz MA. Brief intervention for alcohol use in pregnancy: a randomized trial. Addiction. 1999;94(10):1499-1508. Does not evaluate appropriate intervention. [pmid: 10790902].
54 Charuvastra VC, Dalali ID, Cassuci M, Ling W. Outcome study: comparison of short-term vs long-term treatment in a residential community. Int J Addict. 1992;27(1):15-23. Excluded study design. [pmid: 1537637].
55 Chasnoff IJ, McGourty RF, Bailey GW, Hutchins E, Lightfoot SO, Pawson LL, et al. The 4P's Plus screen for substance use in pregnancy: clinical application and outcomes. Journal of Perinatology. 2005;25(6):368-374. Exclude, kept for background. [pmid: 15703775].
56 Cherpitel CJ, Borges G. Screening for drug use disorders in the emergency department: performance of the rapid drug problems screen (RDPS). Drug & Alcohol Dependence. 2004;74(2):171-175. Exclude, kept for background. [pmid: 15099660].
57 Chiarotti M, Strano-Rossi S, Offidani C, Fiori A. Evaluation of cocaine use during pregnancy through toxicological analysis of hair. Journal of Analytical Toxicology 1996;(7):555–558. Does not report designated outcomes
58 Choopanya K, Des J, Vanichseni S, Mock PA, Kitayaporn D, Sangkhum U, et al. HIV risk reduction in a cohort of injecting drug users in Bangkok, Thailand. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2003;33(1):88-95. Does not report designated outcomes. [pmid: 12792360].
59 Clark KA, Dawson S, Martin SL. The effect of implementing a more comprehensive screening for substance use among pregnant women in North Carolina. Maternal & Child Health Journal. 1999;3(3):161-166. Comparative effectiveness. [pmid: 10746755].
60 Clark N, Lintzeris N, Gijsbers A, Whelan G, Dunlop A, Ritter A et al. LAAM maintenance vs methadone maintenance for heroin dependence. Cochrane Database of Systematic Reviews 2005. Comparative effectiveness
61 Coatsworth JD, Santisteban DA, McBride CK, Szapocznik J. Brief Strategic Family Therapy versus community control: engagement, retention, and an exploration of the moderating role of adolescent symptom severity. Family Process. 2001;40(3):313-32. Excluded for quality. [pmid: 11676271].
62 Cohen MH, Cook JA, Grey D, Young M, Hanau LH, Tien P, et al. Medically eligible women who do not use HAART: the importance of abuse, drug use, and race. Am J Public Health. 2004;94(7):1147-1151. Does not evaluate appropriate intervention. [pmid: 15226135].
63 Collier CR, Czuchry M, Dansereau DF, Pitre U. The use of node-link mapping in the chemical dependency treatment of adolescents. Journal of Drug Education. 2001;31(3):305-17. Comparative effectiveness. [pmid: 11696966].
64 Comer SD, Sullivan MA, Yu E, Rothenberg JL, Kleber HD, Kampman K, et al. Injectable, sustained-release naltrexone for the treatment of opioid dependence: a randomized, placebo-controlled trial. Archives of General Psychiatry. 2006;63(2):210-8. Comparative effectiveness. [pmid: 16461865].
65 Condelli WS, Fairbank JA, Dennis ML, Rachal JV. Cocaine use by clients in methadone programs: significance, scope, and behavioral interventions. J Subst Abuse Treat. 1991;8(4):203-212. Excluded study design. [pmid: 1787544].
66 Cornish JW, Maany I, Fudala PJ, Ehrman RN, Robbins SJ, O'Brien CP. A randomized, double-blind, placebo-controlled study of ritanserin pharmacotherapy for cocaine dependence. Drug & Alcohol Dependence. 2001;61(2):183-9. Comparative effectiveness. [pmid: 11137283].
67 Cornish JW, Maany I, Fudala PJ, Neal S, Poole SA, Volpicelli P, et al. Carbamazepine treatment for cocaine dependence. Drug Alcohol Depend. 1995;38(3):221-227. Excluded for quality. [pmid: 7555622].
68 Cornish JW, Metzger D, Woody GE, Wilson D, McLellan AT, Vandergrift B, et al. Naltrexone pharmacotherapy for opioid dependent federal probationers. J Subst Abuse Treat. 1997;14(6):529-534. Excluded population. [pmid: 9437624].
69 Covi L, Hess JM, Schroeder JR, Preston KL. A dose response study of cognitive behavioral therapy in cocaine abusers. Journal of Substance Abuse Treatment. 2002;23(3):191-7. Comparative effectiveness. [pmid: 12392805].
70 Craig RJ. Sensitivity of MCMI-III Scales T (drugs) and B (alcohol) in detecting substance abuse. Substance Use & Misuse. 1997;32(10):1385-1393. Comparative effectiveness. [pmid: 9286006].
71 Crits-Christoph P, Siqueland L, Blaine J, Frank A, Luborsky L, Onken LS, et al. Psychosocial treatments for cocaine dependence: National Institute on Drug Abuse Collaborative Cocaine Treatment Study. Arch Gen Psychiatry. 1999;56(6):493-502. Excluded study design. [pmid: 10359461].
72 Crits-Christoph P, Siqueland L, McCalmont E, Weiss RD, Gastfriend DR, Frank A, et al. Impact of psychosocial treatments on associated problems of cocaine-dependent patients. Journal of Consulting & Clinical Psychology. 2001;69(5):825-30. Comparative effectiveness. [pmid: 11680559].
73 Crosby RD, Pearson VL, Eller C, Winegarden T, Graves NL. Phenytoin in the treatment of cocaine abuse: a double-blind study. Clin Pharmacol Ther. 1996;59(4):458-468. Excluded for quality. [pmid: 8612392].
74 Curran HV, Collins R, Fletcher S, Kee SC, Woods B, Iliffe S. Older adults and withdrawal from benzodiazepine hypnotics in general practice: effects on cognitive function, sleep, mood and quality of life. Psychological Medicine. 2003;33(7):1223-37. Comparative effectiveness. [pmid: 14580077].
75 Curran S, Savage C. Patient response to naltrexone: issues of acceptance, treatment effects, and frequency of administration. NIDA Res Monogr 1976;(9):67–69. Does not report designated outcomes
76 Curtis NM, Ronan KR, Borduin CM. Multisystemic treatment: a meta-analysis of outcome studies. Journal of Family Psychology. 2004;18(3):411-419. Comparative effectiveness. [pmid: 15382965].
77 D'Alberto A. Auricular acupuncture in the treatment of cocaine/crack abuse: a review of the efficacy, the use of the National Acupuncture Detoxification Association protocol, and the selection of sham points. Journal of Alternative & Complementary Medicine. 2004;10(6):985-1000. Excluded for quality. [pmid: 15673993].
78 Damos DL, Parker ES. High false alarm rates on a vigilance task may indicate recreational drug use. Journal of Clinical & Experimental Neuropsychology. 1994;16(5):713-722. Does not report designated outcomes. [pmid: 7836494].
79 Dashe JS, Sheffield JS, Olscher DA, Todd SJ, Jackson GL, Wendel GD. Relationship between maternal methadone dosage and neonatal withdrawal. Obstetrics & Gynecology. 2002;100(6):1244-1249. Does not evaluate appropriate intervention. [pmid: 12468169].
80 Daumann J Jr, Fischermann T, Heekeren K, Thron A, Gouzoulis-Mayfrank E. Neural mechanisms of working memory in ecstasy (MDMA) users who continue or discontinue ecstasy and amphetamine use: evidence from an 18-month longitudinal functional magnetic resonance imaging study. Biol Psychiatry. 2004;56(5):349-355. Does not report designated outcomes. [pmid: 15336517].
81 Davids E, Gastpar M. Buprenorphine in the treatment of opioid dependence. Eur Neuropsychopharmacol. 2004;14(3):209-216. Excluded study design. [pmid: 15056480].
82 Davis TM, Baer JS, Saxon AJ, Kivlahan DR. Brief motivational feedback improves post-incarceration treatment contact among veterans with substance use disorders. Drug & Alcohol Dependence. 2003;69(2):197-203. Excluded for quality. [pmid: 12609701].
83 Dawe S, Powell J, Richards D, Gossop M, Marks I, Strang J, et al. Does post-withdrawal cue exposure improve outcome in opiate addiction? A controlled trial. Addiction. 1993;88(9):1233-1245. Excluded for quality. [pmid: 8241923].
84 de la TR, Domingo-Salvany A, Badia R, Gonzalez G, McFarlane D, San L, et al. Clinical evaluation of the Triage analytic device for drugs-of-abuse testing. Clinical Chemistry. 1996;42(9):1433-1438. Comparative effectiveness. [pmid: 8787700].
85 Dean AJ, Bell J, Christie MJ, Mattick RP. Depressive symptoms during buprenorphine vs. methadone maintenance: findings from a randomised, controlled trial in opioid dependence. European Psychiatry: the Journal of the Association of European Psychiatrists 1919;(8):510–513. Comparative effectiveness
86 Deas D, Thomas SE. An overview of controlled studies of adolescent substance abuse treatment. American Journal on Addictions. 2001;10(2):178-89. Excluded study design. [pmid: 11444159].
87 Denis C, Fatseas M, Lavie E, Auriacombe M. Pharmacological interventions for benzodiazepine dependence management among benzodiazepine users in outpatient settings. Cochrane Database of Systematic Reviews 2005;(4). Comparative effectiveness
88 Denis C, Lavie E, Fatseas M, Auriacombe M. Psychotherapeutic interventions for cannabis abuse and/or dependence in outpatient settings. Cochrane Database of Systematic Reviews 2005;(4). Comparative effectiveness
89 Dennis M, Godley SH, Diamond G, Tims FM, Babor T, Donaldson J, et al. The Cannabis Youth Treatment (CYT) Study: main findings from two randomized trials. Journal of Substance Abuse Treatment. 2004;27(3):197-213. Excluded study design. [pmid: 15501373].
90 Dhossche D, Rubinstein J. Drug detection in a suburban psychiatric emergency room. Annals of Clinical Psychiatry. 1996;8(2):59-69. Comparative effectiveness. [pmid: 8807030].
91 Dickson PH, Lind A, Studts P, Nipper HC, Makoid M, Therkildsen D. The routine analysis of breast milk for drugs of abuse in a clinical toxicology laboratory. Journal of Forensic Sciences. 1994;39(1):207-214. Does not report designated outcomes. [pmid: 8113701].
92 DiGregorio GJ, Ferko AP, Barbieri EJ, Ruch EK, Chawla H, Keohane D, et al. Determination of cocaine usage in pregnant women by a urinary EMIT drug screen and GC-MS analyses. Journal of Analytical Toxicology. 1994;18(5):247-250. Does not report designated outcomes. [pmid: 7990440].
93 Dijkgraaf MG, van der Zanden BP, de Borgie CA, Blanken P, van Ree JM, van den BW. Cost utility analysis of co-prescribed heroin compared with methadone maintenance treatment in heroin addicts in two randomised trials. BMJ. 2005;330(7503):1297. Excluded study design. [pmid: 15933353].
94 Dolan KA, Shearer J, MacDonald M, Mattick RP, Hall W, Wodak AD. A randomised controlled trial of methadone maintenance treatment versus wait list control in an Australian prison system. Drug Alcohol Depend. 2003;72(1):59-65. Excluded population. [pmid: 14563543].
95 Dolan KA, Shearer J, White B, Zhou J, Kaldor J, Wodak AD. Four-year follow-up of imprisoned male heroin users and methadone treatment: mortality, re-incarceration and hepatitis C infection. Addiction. 2005;100(6):820-828. Excluded setting. [pmid: 15918812].
96 Dole VP, NYSWANDER M. A Medical treatment for diacetylmorphine (heroin) addictions. A Clinical trial with methadone hydrochloride. JAMA. 1965;193:646-650. Exclude, kept for background. [pmid: 14321530].
97 Dole VP, Robinson JW, Orraca J, Towns E, Searcy P, Caine E. Methadone treatment of randomly selected criminal addicts. N Engl J Med. 1969;280(25):1372-1375. Excluded for quality. [pmid: 4890477].
98 Dunn C, Deroo L, Rivara FP. The use of brief interventions adapted from motivational interviewing across behavioral domains: a systematic review. Addiction. 2001;96(12):1725-1742. Kept for use as source document. [pmid: 11784466].
99 Eiler K, Schaefer MR, Salstrom D, Lowery R. Double-blind comparison of bromocriptine and placebo in cocaine withdrawal. Am J Drug Alcohol Abuse. 1995;21(1):65-79. Does not report designated outcomes. [pmid: 7762545].
100 El Mohandes A, Herman AA, Nabil El-Khorazaty M, Katta PS, White D, Grylack L. Prenatal care reduces the impact of illicit drug use on perinatal outcomes. J Perinatol. 2003;23(5):354-360. Does not evaluate appropriate intervention. [pmid: 12847528].
101 Esteban J, Gimeno C, Barril J, Aragones A, Climent JM, de la Cruz PM. Survival study of opioid addicts in relation to its adherence to methadone maintenance treatment. Drug & Alcohol Dependence. 2003;70(2):193-200. Does not evaluate appropriate intervention. [pmid: 12732413].
102 Faggiano F, Vigna-Taglianti F, Versino E, Lemma P. Methadone maintenance at different dosages for opiod dependence. Cochrane Database of Systematic Reviews 2005. Comparative effectiveness
103 Fals-Stewart W. Behavioral family counseling and naltrexone for male opioid-dependent patients. Journal of consulting and clinical psychology 1971;(3). Comparative effectiveness
104 Farre M, Mas A, Torrens M, Moreno V, Cami J. Retention rate and illicit opioid use during methadone maintenance interventions: a meta-analysis. Drug Alcohol Depend. 2002;65(3):283-290. Comparative effectiveness. [pmid: 11841899].
105 Farren CK, O'Malley S. A pilot double blind placebo controlled trial of sertraline with naltrexone in the treatment of opiate dependence. Am J Addict. 2002;11(3):228-234. Comparative effectiveness. [pmid: 12202015].
106 Feldman JG, Minkoff HL, McCalla S, Salwen M. A cohort study of the impact of perinatal drug use on prematurity in an inner-city population. Am J Public Health. 1992;82(5):726-728. Excluded study design. [pmid: 1566952].
107 Fergusson DM, Horwood LJ, Swain-Campbell N. Cannabis use and psychosocial adjustment in adolescence and young adulthood. Addiction. 2002;97(9):1123-1135. Exclude, kept for background. [pmid: 12199828].
108 Ferri M, Davoli M, Perucci CA. Heroin maintenance for chronic heroin dependents. Update of Cochrane Database Syst Rev. 2003. Cochrane Database of Systematic Reviews 2005. Comparative effectiveness
109 Fiellin DA OPC. Methadone maintenance in primary care: a randomized controlled trial. JAMA: the journal of the American Medical Association JAMA, 286(14):1724–31, 2001. Comparative effectiveness
110 Fischer G, Ortner R, Rohrmeister K, Jagsch R, Baewert A, Langer M, et al. Methadone versus buprenorphine in pregnant addicts: A double-blind, double-dummy comparison study. Addiction. Feb. 2006;101(2):275-81. Comparative effectiveness. [pmid: 16445556].
111 Focchi GR, Leite MC, Andrade AG, Scivoletto S. Use of dopamine agonist pergolide in outpatient treatment of cocaine dependence. Substance Use & Misuse. 2005;40(8):1169-77. Comparative effectiveness. [pmid: 16040376].
112 Fox CH. Cocaine use in pregnancy. J Am Board Fam Pract. 1994;7(3):225-228. Does not report designated outcomes. [pmid: 8059626].
113 Friedmann PD, McCullough D, Saitz R. Screening and intervention for illicit drug abuse: a national survey of primary care physicians and psychiatrists. Archives of Internal Medicine. 2001;161(2):248-51. Exclude, kept for background. [pmid: 11176739].
114 Fuller MG, Fishman E, Taylor CA, Wood RB. Screening patients with traumatic brain injuries for substance abuse. Journal of Neuropsychiatry & Clinical Neurosciences. 1994;6(2):143-146. Does not report designated outcomes. [pmid: 8044035].
115 Gadomski A, Bennett S, Young M, Wissow LS. Guidelines for Adolescent Preventive Services: the GAPS in practice. Archives of Pediatrics & Adolescent Medicine. 2003;157(5):426-32. Exclude, kept for background. [pmid: 12742877].
116 Garcia DC, Romero A, Garcia GC, Ostrea EM Jr. Gastric fluid analysis for determining gestational cocaine exposure. Pediatrics 98. 1996;98(2):291-293. Does not report designated outcomes.
117 Gawin FH, Ellinwood EH Jr. Cocaine and other stimulants. Actions, abuse, and treatment. N Engl J Med. 1988;318(18):1173-1182. Exclude, kept for background. [pmid: 3283549].
118 Geller B, Cooper TB, Sun K, Zimerman B, Frazier J, Williams M, et al. Double-blind and placebo-controlled study of lithium for adolescent bipolar disorders with secondary substance dependency. J Am Acad Child Adolesc Psychiatry. 1998;37(2):171-178. Excluded population. [pmid: 9473913].
119 Giacomuzzi S, Kemmler G, Ertl M, Riemer Y. Opioid addicts at admission vs. slow-release oral morphine, methadone, and sublingual buprenorphine maintenance treatment participants. Subst Use Misuse. 2006;41(2):223-44. Comparative effectiveness. [pmid: 16393744].
120 Giannini AJ, Folts DJ, Feather JN, Sullivan BS. Bromocriptine and amantadine in cocaine detoxification. Psychiatry Res. 1989;29(1):11-16. Does not evaluate appropriate intervention. [pmid: 2672061].
121 Giannini AJ, Loiselle RH, Giannini MC. Space-based abstinence: alleviation of withdrawal symptoms in combinative cocaine-phencyclidine abuse. J Toxicol Clin Toxicol. 1987;25(6):493-500. Does not report designated outcomes. [pmid: 3441016].
122 Gibson DR, Flynn NM, McCarthy JJ. Effectiveness of methadone treatment in reducing HIV risk behavior and HIV seroconversion among injecting drug users. Addiction. 2003;13(14):1807-1818. Kept for use as source document.
123 Gibson DR, McCusker J, Chesney M. Effectiveness of psychosocial interventions in preventing HIV risk behaviour in injecting drug users. AIDS. 1998;12(8):919-929. Exclude, kept for background. [pmid: 9631146].
124 Giglio JC. A randomized controlled trial of auricular acupuncture for cocaine dependence: treatments vs outcomes.[comment]. Archives of Internal Medicine 161(6):894 –5; author reply 895, 2001. Does not report designated outcomes
125 Glanz M, Klawansky S, McAullife W, Chalmers T. Methadone vs. l-alpha-acetylmethadol (LAAM) in the treatment of opiate addiction: a meta-analysis of the randomized, controlled trials. Am J Addict. 1997;6(4):339-349. Comparative effectiveness. [pmid: 9398932].
126 Gorelick DA, Wilkins JN. Bromocriptine treatment for cocaine addiction: Association with plasma prolactin levels. Drug Alcohol Depend. Feb 1. 2006;81(2):189-95. Comparative effectiveness. [pmid: 16051446].
127 Gossop M, Marsden J, Stewart D, Kidd T. Changes in use of crack cocaine after drug misuse treatment: 4–5 year follow-up results from the National Treatment Outcome Research Study (NTORS). Drug & Alcohol Dependence. 2002;66(1):21-28. Does not evaluate appropriate intervention. [pmid: 11850132].
128 Gottfredson DC, Wilson DB. Characteristics of effective school-based substance abuse prevention. Prevention Science. 2003;4(1):27-38. Excluded setting. [pmid: 12611417].
129 Gottheil E, Thornton C, Weinstein S. Effectiveness of high versus low structure individual counseling for substance abuse. American Journal on Addictions. 2002;11(4):279-90. Comparative effectiveness. [pmid: 12584871].
130 Gowing L, Ali R, White J. Buprenorphine for the management of opioid withdrawal. Cochrane Database of Systematic Reviews 2005. Excluded study design
131 Gowing L, Ali R, White J. Opioid antagonists and adrenergic agonists for the management of opioid withdrawal. Cochrane Database of Systematic Reviews 2000. Excluded study design
132 Gowing L, Farrell M, Ali R, White J. Alpha2 adrenergic agonists for the management of opioid withdrawal. Cochrane Database of Systematic Reviews 2005. Excluded study design
133 Gowing L, Farrell M, Bornemann R, Ali R. Substitution treatment of injecting opioid users for prevention of HIV infection. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
134 Grabowski J, Rhoades H, Elk R, Schmitz J, Davis C, Creson D, et al. Fluoxetine is ineffective for treatment of cocaine dependence or concurrent opiate and cocaine dependence: two placebo-controlled double-blind trials. J Clin Psychopharmacol. 1995;15(3):163-174. Comparative effectiveness. [pmid: 7635993].
135 Grabowski J, Rhoades H, Schmitz J, Stotts A, Daruzska LA, Creson D, et al. Dextroamphetamine for cocaine-dependence treatment: a double-blind randomized clinical trial. Journal of Clinical Psychopharmacology. 2001;21(5):522-6. Comparative effectiveness. [pmid: 11593078].
136 Grabowski J, Rhoades H, Silverman P, Schmitz JM, Stotts A, Creson D, et al. Risperidone for the treatment of cocaine dependence: randomized, double-blind trial. J Clin Psychopharmacol. 2000;20(3):305-310. Comparative effectiveness. [pmid: 10831016].
137 Greenstein RA, Resnick RB, Resnick E. Methadone and naltrexone in the treatment of heroin dependence. Psychiatr Clin North Am. 1984;7(4):671-679. Excluded study design. [pmid: 6522309].
138 Greenwald MK, Schuh KJ, Hopper JA, Schuster CR, Johanson CE. Effects of buprenorphine sublingual tablet maintenance on opioid drug-seeking behavior by humans. Psychopharmacology. 2002;160(4):344-52. Comparative effectiveness. [pmid: 11919661].
139 Greenwald MK. Early Impact of Methadone Induction for Heroin Dependence: Differential Effects of Two Dose Sequences in a Randomized Controlled Study. Exp Clin Psychopharmacol. Feb. 2006;14(1):52-67. Comparative effectiveness. [pmid: 16503705].
140 Greenwell L, Brecht ML. Self-reported health status among treated methamphetamine users. American Journal of Drug & Alcohol Abuse. 2003;29(1):75-104. Exclude, kept for background. [pmid: 12731682].
141 Greenwood GL, Woods WJ, Guydish J, Bein E. Relapse outcomes in a randomized trial of residential and day drug abuse treatment. Journal of Substance Abuse Treatment. 2001;1920(1):15-23. Comparative effectiveness. [pmid: 11239724].
142 Griffith JD, Rowan-Szal GA, Roark RR, Simpson DD. Contingency management in outpatient methadone treatment: a meta-analysis. Drug Alcohol Depend. 2000;58(12):55-66. Comparative effectiveness. [pmid: 10669055].
143 Gureje O, Vazquez-Barquero JL, Janca A. Comparisons of alcohol and other drugs: experience from the WHO Collaborative Cross-Cultural Applicability Research (CAR) Study. Addiction. 1996;91(10):1529-1538. Exclude, kept for background. [pmid: 8917920].
144 Guttinger F, Gschwend P, Schulte B, Rehm J, Uchtenhagen A. Evaluating long-term effects of heroin-assisted treatment: the results of a 6-year follow-up. Eur Addict Res. 2003;9(2):73-79. Does not evaluate appropriate intervention. [pmid: 12644733].
145 Haemmig RB, Tschacher W. Effects of high-dose heroin versus morphine in intravenous drug users: a randomised double-blind crossover study. Journal of Psychoactive Drugs. 2001;33(2):105-10. Comparative effectiveness. [pmid: 11476257].
146 Halikas JA, Crosby RD, Koop LP, Crea F, Nugent SM, Carlson GA. Daily monitored cardiovascular effects of carbamazepine in chronic crack cocaine users. Psychopharmacol Bull. 1991;27(3):345-351. Does not report designated outcomes. [pmid: 1775609].
147 Hall SM, Tunis S, Triffleman E, Banys P, Clark HW, Tusel D, et al. Continuity of care and desipramine in primary cocaine abusers. J Nerv Ment Dis. 1994;182(10):570-575. Excluded for quality. [pmid: 7931205].
148 Heading CE. Vivitrex (Alkermes/Cephalon). Current Opinion in Investigational Drugs. 2006;7(1):81-8. Does not evaluate appropriate intervention. [pmid: 16425675].
149 Healey A, Knapp M, Marsden J, Gossop M, Stewart D. Criminal outcomes and costs of treatment services for injecting and non-injecting heroin users: evidence from a national prospective cohort survey. Journal of Health Services & Research Policy. 2003;8(3):134-141. Does not evaluate appropriate intervention.
150 Henggeler SW, Clingempeel WG, Brondino MJ, Pickrel SG. Four-year follow-up of multisystemic therapy with substance-abusing and substance-dependent juvenile offenders. Journal of the American Academy of Child & Adolescent Psychiatry. 2002;41(7):868-874. Excluded study design. [pmid: 12108813].
151 Herning RI, Better WE, Tate K, Umbricht A, Preston KL, Cadet JL. Methadone treatment induces attenuation of cerebrovascular deficits associated with the prolonged abuse of cocaine and heroin. Neuropsychopharmacology. 2003;28(3):562-568. Excluded study design. [pmid: 12629538].
152 Hopfer CJ, Khuri E, Crowley TJ, Hooks S. Adolescent heroin use: a review of the descriptive and treatment literature. J Subst Abuse Treat. 2002;23(3):231-237. Comparative effectiveness. [pmid: 12392810].
153 Horrigan TJ, Piazza N. The substance abuse subtle screening inventory minimizes the need for toxicology screening of prenatal patients. Journal of Substance Abuse Treatment. 1999;17(3):243-247. Does not report designated outcomes. [pmid: 10531631].
154 Howard AA, Arnsten JH, Lo Y, Vlahov D, Rich JD, Schuman P, et al. A prospective study of adherence and viral load in a large multi-center cohort of HIV-infected women. AIDS. 2002;16(16):2175-2182. Does not evaluate appropriate intervention. [pmid: 12409739].
155 Hubbard RL, Craddock SG, Anderson J. Overview of 5-year followup outcomes in the drug abuse treatment outcome studies (DATOS). J Subst Abuse Treat. 2003;25(3):125-134. Does not evaluate appropriate intervention. [pmid: 14670518].
156 Hulse GK, Milne E, English DR, Holman CD. Assessing the relationship between maternal opiate use and neonatal mortality. Addiction. 1998;93(7):1033-1042. Excluded for quality. [pmid: 9744134].
157 Humphreys K, Wing S, McCarty D, Chappel J, Gallant L, Haberle B, et al. Self-help organizations for alcohol and drug problems: toward evidence-based practice and policy. J Subst Abuse Treat. 2004;26(3):151-158. Excluded study design. [pmid: 15063905].
158 Irvin JE, Bowers CA, Dunn ME, Wang MC. Efficacy of relapse prevention: a meta-analytic review. Journal of Consulting & Clinical Psychology. 1999;67(4):563-570. Comparative effectiveness. [pmid: 10450627].
159 Jimenez-Lerma JM, Landabaso M, Iraurgi L, Calle R, Sanz J, Gutierrez-Fraile M. Nimodipine in opiate detoxification: a controlled trial. Addiction. 2002;97(7):819-24. Comparative effectiveness. [pmid: 12133120].
160 Jones HE, Haug N, Silverman K, Stitzer M, Svikis D. The effectiveness of incentives in enhancing treatment attendance and drug abstinence in methadone-maintained pregnant women. Drug & Alcohol Dependence. 2001;61(3):297-306. Excluded for quality. [pmid: 11164694].
161 Jones HE, Johnson RE, Bigelow GE, Silverman K, Mudric T, Strain EC. Safety and efficacy of L-tryptophan and behavioral incentives for treatment of cocaine dependence: a randomized clinical trial. American Journal on Addictions. 2004;13(5):421-37. Excluded population. [pmid: 15764421].
162 Jones HE, Johnson RE, Jasinski DR, O'Grady KE, Chisholm CA, Choo RE, et al. Buprenorphine versus methadone in the treatment of pregnant opioid-dependent patients: effects on the neonatal abstinence syndrome. Drug & Alcohol Dependence. 2005;79(1):1-10. Comparative effectiveness. [pmid: 15943939].
163 Jones HE, Wong CJ, Tuten M, Stitzer ML. Reinforcement-based therapy: 12-month evaluation of an outpatient drug-free treatment for heroin abusers. Drug Alcohol Depend. Aug 1. 2005;79(2):119-28. Comparative effectiveness. [pmid: 16002021].
164 Kaminer Y, Burleson JA, Goldberger R. Cognitive-behavioral coping skills and psychoeducation therapies for adolescent substance abuse. Journal of Nervous & Mental Disease 190;(11):737–745. Comparative effectiveness
165 Kampman K, Volpicelli JR, Alterman A, Cornish J, Weinrieb R, Epperson L, et al. Amantadine in the early treatment of cocaine dependence: a double-blind, placebo-controlled trial. Drug Alcohol Depend. 1996;41(1):25-33. Comparative effectiveness. [pmid: 8793307].
166 Kampman KM PH. A pilot trial of topiramate for cocaine dependence. Drug and alcohol dependence 1975;(3). Comparative effectiveness
167 Kampman KM VJM. Effectiveness of propranolol for cocaine dependence treatment may depend on cocaine withdrawal symptom severity. Drug and alcohol dependence 1963; 63(1):69–78. Comparative effectiveness
168 Kampman KM, Leiderman D, Holmes T, LoCastro J, Bloch DA, Reid MS, et al. Cocaine Rapid Efficacy Screening Trials (CREST): lessons learned. Addiction. 2005;100:102-110. Excluded study design. [pmid: 15730354].
169 Kampman KM, Rukstalis M, Ehrman R, McGinnis DE, Gariti P, Volpicelli JR, et al. Open trials as a method of prioritizing medications for inclusion in controlled trials for cocaine dependence. Addict Behav. 1999;24(2):287-291. Excluded study design. [pmid: 10336110].
170 Kampman KM, Volpicelli JR, Alterman AI, Cornish J, O'Brien CP. Amantadine in the treatment of cocaine-dependent patients with severe withdrawal symptoms. Am J Psychiatry. 2000;157(12):2052-2054. Does not evaluate appropriate intervention. [pmid: 11097979].
171 Kaul P, Coupey SM. Clinical evaluation of substance abuse. Pediatrics in Review. 2002;23(3):85-94. Does not evaluate appropriate intervention. [pmid: 11875181].
172 Kim E, Brion LP, Meenan G, Lehrer M, Suresh BR. Perinatal toxicology screening: comparison of various maternal and neonatal samples. Journal of Perinatology. 1998;18(2):116-121. Comparative effectiveness. [pmid: 9605301].
173 Kim YH, Schiff E, Waalen J, Hovell M. Efficacy of acupuncture for treating cocaine addiction: A review paper. J Addict Dis. 2005;24(4):115-32. Kept for use as source document. [pmid: 16368661].
174 Kirchmayer U, Davoli M, Verster A. Naltrexone maintenance treatment for opioid dependence. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
175 Kirchmayer U, Davoli M, Verster AD, Amato L, Ferri M, Perucci CA. A systematic review on the efficacy of naltrexone maintenance treatment in opioid dependence. Addiction. 2002;97(10):1241-1249. Kept for use as source document. [pmid: 12359026].
176 Klein J, Karaskov T, Koren G. Clinical applications of hair testing for drugs of abuse—the Canadian experience. Forensic Science International. 2000;107(13):281-288. Does not report designated outcomes. [pmid: 10689580].
177 Knight JR, Sherritt L, Shrier LA, Harris SK, Chang G. Validity of the CRAFFT substance abuse screening test among adolescent clinic patients. Archives of Pediatrics & Adolescent Medicine. 2002;156(6):607-614. Exclude, kept for background. [pmid: 12038895].
178 Knight JR, Sherritt L, Van Hook S, Gates EC, Levy S, Chang G. Motivational interviewing for adolescent substance use: a pilot study. Journal of Adolescent Health. 2005;37(2):167-9. Excluded for quality. [pmid: 16026730].
179 Kongsakon R, Papadopoulos KI, Saguansiritham R. Mirtazapine in amphetamine detoxification: A placebo-controlled pilot study. Int Clin Psychopharmacol. Sep. 2005;20(5):253-6. 2005. Does not report designated outcomes. [pmid: 16096515].
180 Koren G, Klein J. Neonatal hair test for cocaine. Toronto experience. Canadian Family Physician. 1997;43(1215):1217-1219. Does not report designated outcomes. [pmid: 9241456].
181 Kreek MJ, LaForge KS, Butelman E. Pharmacotherapy of addictions. Nat Rev Drug Discov. 2002;1(9):710-726. Exclude, kept for background. [pmid: 12209151].
182 Kreek MJ. Methadone-related opioid agonist pharmacotherapy for heroin addiction. History, recent molecular and neurochemical research and future in mainstream medicine. Ann N Y Acad Sci. 2000;909:186-216. Exclude, kept for background. [pmid: 10911931].
183 Kristensen O. Buprenorphine and methadone to opiate addicts—a randomized trial. Tidsskrift for den Norske laegeforening. Jan 20. 2005;125(2):148-51. Comparative effectiveness. [pmid: 15665884].
184 Krupitsky E, Burakov A, Romanova T, Dunaevsky I, Strassman R, Grinenko A. Ketamine psychotherapy for heroin addiction: Immediate effects and two-year follow-up. J Subst Abuse Treat. 2002;23(4):273-83. Comparative effectiveness. [pmid: 12495789].
185 Kumpfer KL, Alvarado R, Whiteside HO. Family-based interventions for substance use and misuse prevention. Substance Use & Misuse. 2003;38(1113):1759-1787. Does not report designated outcomes. [pmid: 14582577].
186 Kwiatkowski CF, Booth RE. Methadone maintenance as HIV risk reduction with street-recruited injecting drug users. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2001;26(5):483-489. Does not evaluate appropriate intervention. [pmid: 11391170].
187 Ladewig D. Naltrexone—an effective aid in the psychosocial rehabilitation process of former opiate dependent patients Naltrexon—eine wirksame Stutze im psychosozialen Rehabilitationsprozess ehemals Opiatabhangiger. Ther Umsch. 1990;47(3):247-250. Non-English. [pmid: 2187266].
188 Lake J. Psychotropic medications from natural products: a review of promising research and recommendations. Alternative Therapies in Health & Medicine. 2000;6(3):36-45. Excluded study design. [pmid: 10802907].
189 Langendam MW, van Brussel GH, Coutinho RA, van Ameijden EJ. The impact of harm-reduction-based methadone treatment on mortality among heroin users. Am J Public Health. 2001;91(5):774-780. Does not evaluate appropriate intervention. [pmid: 11344886].
190 Latimer WW, Winters KC, D'Zurilla T, Nichols M. Integrated family and cognitive-behavioral therapy for adolescent substance abusers: a stage I efficacy study. Drug & Alcohol Dependence. 2003;71(3):303-17. Comparative effectiveness. [pmid: 12957348].
191 Leiderman DB, Shoptaw S, Montgomery A, Bloch DA, Elkashef A, LoCastro J, et al. Cocaine Rapid Efficacy Screening Trial (CREST): a paradigm for the controlled evaluation of candidate medications for cocaine dependence. Addiction. 2005;100(Suppl 1):1-11. Comparative effectiveness. [pmid: 15773068].
192 Lemoine P, Kermadi I, Garcia-Acosta S, Garay RP, Dib M. Double-blind, comparative study of cyamemazine vs. bromazepam in the benzodiazepine withdrawal syndrome. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2006;30(1):131-7. Comparative effectiveness. [pmid: 16243418].
193 Lerner A, Sigal M, Bacalu A, Shiff R, Burganski I, Gelkopf M. A naltrexone double blind placebo controlled study in Israel. Isr J Psychiatry Relat Sci. 1992;29(1):36-43. Excluded for quality. [pmid: 1568861].
194 Leshner AI. Science-based views of drug addiction and its treatment. JAMA. 1999;282(14):1314-6. Exclude, kept for background. [pmid: 10527162].
195 Levin FR, McDowell D, Evans SM, Nunes E, Akerele E, Donovan S, et al. Pharmacotherapy for marijuana dependence: a double-blind, placebo-controlled pilot study of divalproex sodium. American Journal on Addictions. 2004;13(1):21-32. Feb. Comparative effectiveness. [pmid: 14766435].
196 Liddle HA, Dakof GA, Parker K, Diamond GS, Barrett K, Tejeda M. Multidimensional family therapy for adolescent drug abuse: results of a randomized clinical trial. American Journal of Drug & Alcohol Abuse. 2001;27(4):651-88. Comparative effectiveness. [pmid: 11727882].
197 Lima MS, Reisser Lima AAP, Soares BGO, Farrell M. Antidepressants for cocaine dependence]. Cochrane Database of Systematic Reviews 2003. Kept for use as source document
198 Lima Reisser A, Lima MS, Soares BGO, Farrell M. Carbamazepine for cocaine dependence. Cochrane Database of Systematic Reviews 2002. Kept for use as source document
199 Linde K, Vickers A, Hondras M, ter Riet G, Thormahlen J, Berman B, et al. Systematic reviews of complementary therapies - an annotated bibliography. Part 1: acupuncture. BMC Complement Altern Med. 2001;1:3. Non-English. [pmid: 11513758].
200 Ling W, Charuvastra C, Collins JF, Batki S, Brown LS Jr, Kintaudi P, et al. Buprenorphine maintenance treatment of opiate dependence: a multicenter, randomized clinical trial. Addiction. 1998;93(4):475-486. Excluded for quality. [pmid: 9684386].
201 Litt MD, Kadden RM, Stephens RS. Coping and Self-Efficacy in Marijuana Treatment: Results From the Marijuana Treatment Project. J Consult Clin Psychol. Dec. 2005;73(6):1015-25. Exclude, kept for background. [pmid: 16392975].
202 Lollis CM, Strothers HS, Chitwood DD, McGhee M. Sex, drugs, and HIV: does methadone maintenance reduce drug use and risky sexual behavior?. J Behav Med. 2000;23(6):545-557. Does not evaluate appropriate intervention. [pmid: 11199087].
203 Longshore D, Grills C, Annon K. Effects of a culturally congruent intervention on cognitive factors related to drug-use recovery. Subst Use Misuse. 1999;34(9):1223-1241. Does not report designated outcomes. [pmid: 10419221].
204 Longshore D, Hsieh S, Danila B, Anglin MD. Methadone maintenance and needle/syringe sharing. Int J Addict. 1993;28(10):983-996. Excluded study design. [pmid: 8407026].
205 Magura S, Staines GL, Blankertz L, Madison EM. The effectiveness of vocational services for substance users in treatment. Subst Use Misuse. 2004;39(1314):2165-2213. Excluded study design. [pmid: 15603001].
206 Malcolm R, Herron J, Sutherland SE, Brady KT. Adverse outcomes in a controlled trial of pergolide for cocaine dependence. Journal of Addictive Diseases. 2001;1920(1):81-92. Comparative effectiveness. [pmid: 11286433].
207 Malcolm R, Kajdasz DK, Herron J, Anton RF, Brady KT. A double-blind, placebo-controlled outpatient trial of pergolide for cocaine dependence. Drug Alcohol Depend. 2000;60(2):161-168. Comparative effectiveness. [pmid: 10940543].
208 Malcolm R, LaRowe S, Cochran K, Moak D, Herron J, Brady K, et al. A controlled trial of amlodipine for cocaine dependence: a negative report. Journal of Substance Abuse Treatment. 2005;28(2):197-204. Comparative effectiveness. [pmid: 15780550].
209 Margolin A, Avants SK, Holford TR. Interpreting conflicting findings from clinical trials of auricular acupuncture for cocaine addiction: does treatment context influence outcome?. Journal of Alternative & Complementary Medicine. 2002;8(2):111-21. Comparative effectiveness. [pmid: 12006119].
210 Margolin A, Kleber HD, Avants SK, Konefal J, Gawin F, Stark E, et al. Acupuncture for the treatment of cocaine addiction: a randomized controlled trial. JAMA. 2002;287(1):55-63. Comparative effectiveness. [pmid: 11754709].
211 Margolin A, Kosten TR, Avants SK, Wilkins J, Ling W, Beckson M, et al. A multicenter trial of bupropion for cocaine dependence in methadone-maintained patients. Drug Alcohol Depend. 1995;40(2):125-131. Excluded population. [pmid: 8745134].
212 Margolin A. Acupuncture for substance abuse. Current Psychiatry Reports. 2003;5(5):333-9. Comparative effectiveness. [pmid: 13678552].
213 Marques AC, Formigoni ML. Comparison of individual and group cognitive-behavioral therapy for alcohol and/or drug-dependent patients. Addiction. 2001;96(6):835-46. Comparative effectiveness. [pmid: 11399215].
214 Marsch LA. The efficacy of methadone maintenance interventions in reducing illicit opiate use, HIV risk behavior and criminality: a meta-analysis. Addiction. 1998;93(4):515-532. Kept for use as source document. [pmid: 9684390].
215 Marsden J, Gossop M, Stewart D, Best D, Farrell M, Lehmann P, et al. The Maudsley Addiction Profile (MAP): a brief instrument for assessing treatment outcome. Addiction. 1998;93(12):1857-1867. Does not report designated outcomes. [pmid: 9926574].
216 Mattick RP, Breen C, Kimber J, Davoli M. Methadone maintenance therapy versus no opioid replacement therapy for opioid dependence. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
217 Mattick RP, Kimber J, Breen C, Davoli M. Buprenorphine maintenance versus placebo or methadone maintenance for opioid dependence. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
218 Mayet S, Farrell M, Ferri M, Amato L, Davoli M. Psychosocial treatment for opiate abuse and dependence. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
219 McCarthy G, Myers B, Siegfried N. Treatment for Methaqualone dependence in adults. Cochrane Database of Systematic Reviews 2005. Excluded setting
220 McCarthy JJ, Leamon MH, Parr MS, Anania B. High-dose methadone maintenance in pregnancy: maternal and neonatal outcomes. American Journal of Obstetrics & Gynecology. 2005;193(3 Pt 1):606-610. Does not evaluate appropriate intervention. [pmid: 16150249].
221 Mcclanahan TM. A comparative evaluation of cognitive-behavioral therapy and insight-oriented psychotherapy in the treatment of comorbid substance abuse, anxiety, and depression in substance abusing females. 2001. Dissertation. Comparative effectiveness
222 McCoy CB, Metsch LR, Comerford M, Zhao W, Coltes AJ, Messiah SE. Trends of HIV risk behaviors in a cohort of injecting drug users and their sex partners in Miami, Florida, 1988-1998. AIDS & Behavior. 2005;9(2):187-199. Does not evaluate appropriate intervention. [pmid: 15933838].
223 McKay JR LKSDPH. The Effectiveness of Telephone-Based Continuing Care for Alcohol and Cocaine Dependence. Archives of General Psychiatry 1962;(2). Comparative effectiveness
224 McKay JR, Lynch KG, Pettinati HM, Shepard DS. An examination of potential sex and race effects in a study of continuing care for alcohol- and cocaine- dependent patients. Alcohol Clin Exp Res. 2003;27(8):1321-3. Comparative effectiveness. [pmid: 12966329].
225 McKay JR, Merikle E, Mulvaney FD, Weiss RV, Koppenhaver JM. Factors accounting for cocaine use two years following initiation of continuing care. Addiction. 2001;96(2):213-25. Comparative effectiveness. [pmid: 11182866].
226 McLellan AT, Lewis DC, O'Brien CP, Kleber HD. Drug dependence, a chronic medical illness: implications for treatment, insurance, and outcomes evaluation. JAMA. 2000;284(13):1689-1695. Exclude, kept for background. [pmid: 11015800].
227 Meandzija B, O'Connor PG, Fitzgerald B, Rounsaville BJ, Kosten TR. HIV infection and cocaine use in methadone maintained and untreated intravenous drug users. Drug & Alcohol Dependence. 1994;36(2):109-113. Excluded study design. [pmid: 7851277].
228 Meeker JE, Mount AM, Ross W. Detection of drug abuse by health professionals. Occupational Health & Safety. 2002;71(8):46-50. Does not evaluate appropriate intervention. [pmid: 12197441].
229 Meier PS, Barrowclough C, Donmall MC. The role of the therapeutic alliance in the treatment of substance misuse: a critical review of the literature. Addiction. 2005;100(3):304-316. Does not evaluate appropriate intervention. [pmid: 15733244].
230 Mello NK, Mendelson JH, Kuehnle JC, Sellers MS. Operant analysis of human heroin self-administration and the effects of naltrexone. J Pharmacol Exp Ther. 1981;216(1):45-54. Does not evaluate appropriate intervention. [pmid: 7452507].
231 Messina N, Farabee D, Rawson R. Treatment responsivity of cocaine-dependent patients with antisocial personality disorder to cognitive-behavioral and contingency management interventions. Journal of Consulting & Clinical Psychology. 2003;71(2):320-329. Excluded study design. [pmid: 12699026].
232 Metrebian N. Prescribing drug of choice to opiate dependent drug users: a comparison of clients receiving heroin with those receiving injectable methadone at a West London drug clinic. Drug and alcohol review 1920;(3). Comparative effectiveness
233 Metzger DS, Woody GE, McLellan AT, O'Brien CP, Druley P, Navaline H, et al. Human immunodeficiency virus seroconversion among intravenous drug users in- and out-of-treatment: an 18-month prospective follow-up. J Acquir Immune Defic Syndr. 1993;6(9):1049-1056. Excluded study design. [pmid: 8340896].
234 Midanik LT, Zahnd EG, Klein D. Alcohol and drug CAGE screeners for pregnant, low-income women: the California Perinatal Needs Assessment. Alcoholism: Clinical & Experimental Research. 1998;22(1):121-125. Does not report designated outcomes.
235 Miller WR, Yahne CE, Tonigan JS. Motivational interviewing in drug abuse services: A randomized trial. J Consult Clin Psychol. Aug. 2003;71(4):754-63. Comparative effectiveness. [pmid: 12924680].
236 Milton S, Crino R, Hunt C, Prosser E. The effect of compliance-improving interventions on the cognitive-behavioural treatment of pathological gambling. J Gambl Stud. 2002;18(2):207-229. Does not evaluate appropriate intervention. [pmid: 12096449].
237 Modestin J, Nussbaumer C, Angst K, Scheidegger P, Hell D. Use of potentially abusive psychotropic substances in psychiatric inpatients. European Archives of Psychiatry & Clinical Neuroscience. 1997;247(3):146-153. Does not report designated outcomes. [pmid: 9224907].
238 Moner SE. Acupuncture and addiction treatment. J Addict Dis. 1996;15(3):79-100. Excluded for quality. [pmid: 8842852].
239 Montoya ID PKR. Open-label pilot study of bupropion plus bromocriptine for treatment of cocaine dependence. American Journal of Drug and Alcohol Abuse 1928;(1). Comparative effectiveness
240 Montoya ID, Gorelick DA, Preston KL, Schroeder JR, Umbricht A, Cheskin LJ, et al. Randomized trial of buprenorphine for treatment of concurrent opiate and cocaine dependence. Clin Pharmacol Ther. 2004;75(1):34-48. Comparative effectiveness. [pmid: 14749690].
241 Montoya ID, Levin FR, Fudala PJ, Gorelick DA. Double-blind comparison of carbamazepine and placebo for treatment of cocaine dependence. Drug Alcohol Depend. 1995;38(3):213-219. Comparative effectiveness. [pmid: 7555621].
242 Morgenstern J, Blanchard KA, Morgan TJ, Labouvie E, Hayaki J. Testing the effectiveness of cognitive-behavioral treatment for substance abuse in a community setting: within treatment and posttreatment findings. Journal of Consulting & Clinical Psychology. 2001;69(6):1007-17. Comparative effectiveness. [pmid: 11777104].
243 Morgenstern J, Bux DAJ, Labouvie E, Morgan T, Blanchard KA, Muench F. Examining mechanisms of action in 12-Step community outpatient treatment. Drug Alcohol Depend. 2003;72(3):237-47. Comparative effectiveness. [pmid: 14643940].
244 Musselman DL, Kell MJ. Prevalence and improvement in psychopathology in opioid dependent patients participating in methadone maintenance. J Addict Dis. 1995;14(3):67-82. Does not evaluate appropriate intervention. [pmid: 8555280].
245 National Institute on Drug Abuse. Prescription Medication. 10-5-2005. Exclude, kept for background
246 National Research Council, Institute of Medicine. New Treatments for Addiction: Behavioral, Ethical, Legal and Social Questions. Washington, DC: National Academies Press, 2004. Exclude, kept for background
247 Nich C, McCance-Katz EF, Petrakis IL, Cubells JF, Rounsaville BJ, Carroll KM. Sex differences in cocaine-dependent individuals' response to disulfiram treatment. Addict Behav. 2004;29(6):1123-1128. Excluded study design. [pmid: 15236812].
248 Nunes EV, McGrath PJ, Quitkin FM, Ocepek-Welikson K, Stewart JW, Koenig T, et al. Imipramine treatment of cocaine abuse: possible boundaries of efficacy. Drug Alcohol Depend. 1995;39(3):185-195. Comparative effectiveness. [pmid: 8556967].
249 O'Connor AD, Rusyniak DE, Bruno A. Cerebrovascular and cardiovascular complications of alcohol and sympathomimetic drug abuse. Med Clin North Am. 2005;89(6):1343-1358. Exclude, kept for background. [pmid: 16227066].
250 Office of National Drug Control Policy. Healing America's Drug Users: Getting Treatment Resources Where They Are Needed. 2005. Exclude, kept for background
251 O'Leary Tevyaw T, Monti PM. Motivational enhancement and other brief interventions for adolescent substance abuse: Foundations, applications and evaluations. Addiction. 2004;99(Suppl 2):63-75. Exclude, kept for background. [pmid: 15488106].
252 Parran T Jr, Weber E, Tasse J, Anderson B, Adelman C. Mandatory toxicology testing and chemical dependence consultation follow-up in a level-one trauma center. Journal of Trauma-Injury Infection & Critical Care. 1995;38(2):278-280. Comparative effectiveness.
253 Peck JA, Reback CJ, Yang X, Rotheram-Fuller E, Shoptaw S. Sustained reductions in drug use and depression symptoms from treatment for drug abuse in methamphetamine-dependent gay and bisexual men. J Urban Health. 2005;82(1 Suppl 1):i100-i108. Does not report designated outcomes. [pmid: 15738315].
254 Peirce JM, Petry NM, Stitzer ML, Blaine J, Kellogg S, Satterfield F, et al. Effects of lower-cost incentives on stimulant abstinence in methadone maintenance treatment: a National Drug Abuse Treatment Clinical Trials Network study. Archives of General Psychiatry. 2006;63(2):201-8. Comparative effectiveness. [pmid: 16461864].
255 Petitjean S, Stohler R, Deglon JJ, Livoti S, Waldvogel D, Uehlinger C, et al. Double-blind randomized trial of buprenorphine and methadone in opiate dependence. Drug & Alcohol Dependence. 2001;62(1):97-104. Comparative effectiveness. [pmid: 11173173].
256 Petrie J, Bunn F, Byrne G. Parenting programmes for preventing tobacco, alcohol or drugs abuse in children under 18. Cochrane Database of Systematic Reviews 2005. Comparative effectiveness
257 Petry NM, Petrakis I, Trevisan L, Wiredu G, Boutros NN, Martin B, et al. Contingency management interventions: from research to practice. American Journal of Psychiatry. 2001;158(5):694-702. Comparative effectiveness. [pmid: 11329388].
258 Poling J, Oliveto A, Petry N, Sofuoglu M, Gonsai K, Gonzalez G, et al. Six-month trial of bupropion with contingency management for cocaine dependence in a methadone-maintained population. Archives of General Psychiatry. 2006;63(2):219-28. Comparative effectiveness. [pmid: 16461866].
259 Pope HG Jr, Gruber AJ, Hudson JI, Cohane G, Huestis MA, Yurgelun-Todd D. Early-onset cannabis use and cognitive deficits: what is the nature of the association?. Drug & Alcohol Dependence. 2003;69(3):303-310. Does not evaluate appropriate intervention. [pmid: 12633916].
260 Power R, Hartnoll R, Chalmers C. Help-seeking among illicit drug users: some differences between a treatment and nontreatment sample. Int J Addict. 1992;27(8):887-904. Excluded study design. [pmid: 1322382].
261 Prendergast ML, Podus D, Chang E. Program factors and treatment outcomes in drug dependence treatment: an examination using meta-analysis. Substance Use & Misuse. 2000;35(1214):1931-1965. Does not evaluate appropriate intervention. [pmid: 11138713].
262 Preston KL, Umbricht A, Epstein DH. Methadone dose increase and abstinence reinforcement for treatment of continued heroin use during methadone maintenance. Arch Gen Psychiatry. 2000;57(4):395-404. Excluded study design. [pmid: 10768702].
263 Preston KL, Umbricht A, Wong CJ, Epstein DH. Shaping cocaine abstinence by successive approximation. Journal of Consulting & Clinical Psychology. 2001;69(4):643-54. Comparative effectiveness. [pmid: 11550730].
264 Rabinowitz J. Outcomes of Naltrexone Maintenance Following Ultra Rapid Opiate Detoxification Versus Intensive Inpatient Detoxification. American Journal on Addictions 1911;(1). Comparative effectiveness
265 Racine AD, Joyce TJ, Anderson R. The association between prenatal care and birth weight among women exposed to cocaine in New York City: a correction. JAMA. 1994;271(15):1161-1162. Excluded study design. [pmid: 7908704].
266 Raisch DW, Fye CL, Boardman KD, Sather MR. Opioid dependence treatment, including buprenorphine/naloxone. Annals of Pharmacotherapy. 2002;36(2):312-21. Exclude, kept for background. [pmid: 11847954].
267 Rawson RA, Huber A, McCann M, Shoptaw S, Farabee D, Reiber C, et al. A comparison of contingency management and cognitive-behavioral approaches during methadone maintenance treatment for cocaine dependence. Archives of General Psychiatry. 2002;59(9):817-24. Comparative effectiveness. [pmid: 12215081].
268 Rawson RA, Marinelli-Casey P, Anglin MD, Dickow A, Frazier Y, Gallagher C, et al. A multi-site comparison of psychosocial approaches for the treatment of methamphetamine dependence. Addiction. 2004;99(6):708-717. Comparative effectiveness. [pmid: 15139869].
269 Rawson RA, Tennant FS Jr. Five-year follow-up of opiate addicts with naltrexone and behavior therapy. NIDA Res Monogr. 1984;49:289-295. Excluded for quality. [pmid: 6434974].
270 Rayburn WF, Bogenschutz MP. Pharmacotherapy for pregnant women with addictions. American Journal of Obstetrics & Gynecology 191;(6):1885–1897. Excluded for quality
271 Rayburn WF, Bogenschutz MP. Pharmacotherapy for pregnant women with addictions. American Journal of Obstetrics & Gynecology 2004;(6):1885–1897. Excluded study design
272 Reid MS, Angrist B, Baker S, Woo C, Schwartz M, Montgomery A, et al. A placebo-controlled screening trial of celecoxib for the treatment of cocaine dependence. Addiction. 2005;100(Suppl 1):32-42. Comparative effectiveness. [pmid: 15730348].
273 Remien RH, Goetz R, Rabkin JG, Williams JB, Bradbury M, Ehrhardt AA, et al. Remission of substance use disorders: gay men in the first decade of AIDS. J Stud Alcohol. 1995;56(2):226-232. Does not evaluate appropriate intervention. [pmid: 7760570].
274 Reynaud-Maurupt C, Carrieri MP, Gastaud JA, Pradier C, Obadia Y, Moatti JP. Impact of drug maintenance treatment on injection practices among French HIV-infected IDUs. The MANIF 2000 Study Group. AIDS Care. 2000;12(4):461-470. Does not evaluate appropriate intervention. [pmid: 11091779].
275 Riggs PD, Hall SK, Mikulich-Gilbertson SK, Lohman M, Kayser A. A randomized controlled trial of pemoline for attention-deficit/hyperactivity disorder in substance-abusing adolescents. J Am Acad Child Adolesc Psychiatry. 2004;43(4):420-429. Excluded population. [pmid: 15187802].
276 Ritter AJ, Lintzeris N, Clark N, Kutin JJ, Bammer G, Panjari M. A randomized trial comparing levo-alpha acetylmethadol with methadone maintenance for patients in primary care settings in Australia. Addiction. 2003;98(11):1605-13. Comparative effectiveness. [pmid: 14616187].
277 Robertson JR, Ronald PJ, Raab GM, Ross AJ, Parpia T. Deaths, HIV infection, abstinence, and other outcomes in a cohort of injecting drug users followed up for 10 years. BMJ. 1994;309(6951):369-372. Does not evaluate appropriate intervention. [pmid: 8081134].
278 Rogne GS, Myrvang B, Opjordsmoen S. Criminality in drug addicts: a follow-up study over 25 years. Eur Addict Res. 2004;10(2):49-55. Does not evaluate appropriate intervention. [pmid: 15004447].
279 Roozen HG, Boulogne JJ, van Tulder MW, van den BW, De Jong CA, Kerkhof AJ. A systematic review of the effectiveness of the community reinforcement approach in alcohol, cocaine and opioid addiction. Drug & Alcohol Dependence. 2004;74(1):1-13. Excluded for quality. [pmid: 15072802].
280 Rosenbaum M, Washburn A, Knight K, Kelley M, Irwin J. Treatment as harm reduction, defunding as harm maximization: the case of methadone maintenance. J Psychoactive Drugs. 1996;28(3):241-249. Does not evaluate appropriate intervention. [pmid: 8895109].
281 Saleh SS, Vaughn T, Hall J, Levey S, Fuortes L, Uden-Holmen T. Effectiveness of case management in substance abuse treatment. Care Management Journals. 2002;3(4):172-7. Excluded population. [pmid: 12847933].
282 Saunders B, Wilkinson C, Phillips M. The impact of a brief motivational intervention with opiate users attending a methadone programme. Addiction. 1995;90(3):415-424. Excluded for quality. [pmid: 7735025].
283 Schildhaus S, Gerstein D, Brittingham A, Cerbone F, Dugoni B. Services research outcomes study: overview of drug treatment population and outcomes. Substance Use & Misuse. 2000;35(1214):1849-1877. Does not evaluate appropriate intervention. [pmid: 11138710].
284 Schmitz JM, Averill P, Stotts AL, Moeller FG, Rhoades HM, Grabowski J. Fluoxetine treatment of cocaine-dependent patients with major depressive disorder. Drug & Alcohol Dependence. 2001;63(3):207-14. Comparative effectiveness. [pmid: 11418225].
285 Schottenfeld RS, Pakes JR, Kosten TR. Prognostic factors in Buprenorphine- versus methadone-maintained patients. Journal of Nervous & Mental Disease. 1998;186(1):35-43. Does not report designated outcomes. [pmid: 9457145].
286 Schumacher JE, Milby JB, Raczynski JM, Caldwell E, Engle M, Carr J, et al. Validity of self-reported crack cocaine use among homeless persons in treatment. Journal of Substance Abuse Treatment. 1995;12(5):335-339. Does not report designated outcomes. [pmid: 8583516].
287 Scott CK, Dennis ML, Foss MA. Utilizing Recovery Management Checkups to shorten the cycle of relapse, treatment reentry, and recovery. Drug & Alcohol Dependence. 2005;78(3):325-38. Does not report designated outcomes. [pmid: 15893164].
288 Sees KL, Delucchi KL, Masson C, Rosen A, Clark HW, Robillard H, et al. Methadone maintenance vs 180-day psychosocially enriched detoxification for treatment of opioid dependence: a randomized controlled trial. JAMA. 2000;283(10):1303-1310. Excluded for quality. [pmid: 10714729].
289 Sege R, Stringham P, Short S, Griffith J. Ten years after: examination of adolescent screening questions that predict future violence-related injury. Journal of Adolescent Health. 1999;24(6):395-402. Does not report designated outcomes. [pmid: 10401967].
290 Seifert J, Metzner C, Paetzold W, Borsutzky M, Passie T, Rollnik J, et al. Detoxification of opiate addicts with multiple drug abuse: a comparison of buprenorphine vs. methadone. Pharmacopsychiatry. 2002;35(5):159-64. Comparative effectiveness. [pmid: 12237786].
291 Serpelloni G, Carrieri MP, Rezza G, Morganti S, Gomma M, Binkin N. Methadone treatment as a determinant of HIV risk reduction among injecting drug users: a nested case-control study. AIDS Care. 1994;6(2):215-220. Excluded study design. [pmid: 8061081].
292 Shoptaw S, Watson DW, Reiber C, Rawson RA, Montgomery MA, Majewska MD, et al. Randomized controlled pilot trial of cabergoline, hydergine and levodopa/carbidopa: Los Angeles Cocaine Rapid Efficacy Screening Trial (CREST). Addiction. 2005;100(Suppl 1):78-90. Comparative effectiveness. [pmid: 15730352].
293 Shufman EN, Porat S, Witztum E, Gandacu D, Bar-Hamburger R, Ginath Y. The efficacy of naltrexone in preventing reabuse of heroin after detoxification. Biol Psychiatry. 1994;35(12):935-945. Excluded for quality. [pmid: 8080893].
294 Silva dL, Oliveira Soares BG, Pereira Reisser AA, Farrell M. Pharmacological treatment of cocaine dependence: a systematic review. Addiction. 2002;97(8):931-949. Kept for use as source document. [pmid: 12144591].
295 Silverman K, Svikis D, Robles E, Stitzer ML, Bigelow GE. A reinforcement-based therapeutic workplace for the treatment of drug abuse: six-month abstinence outcomes. Experimental & Clinical Psychopharmacology. 2001;9(1):14-23. Excluded for quality. [pmid: 11519628].
296 Silverman K, Wong CJ, Higgins ST, Brooner RK, Montoya ID, Contoreggi C, et al. Increasing opiate abstinence through voucher-based reinforcement therapy. Drug Alcohol Depend. 1996;41(2):157-165. Excluded study design. [pmid: 8809505].
297 Simoens S, Matheson C, Bond C, Inkster K, Ludbrook A. The effectiveness of community maintenance with methadone or buprenorphine for treating opiate dependence. Br J Gen Pract. 2005;55(511):139-146. Comparative effectiveness. [pmid: 15720937].
298 Simpson TL, Westerberg VS, Little LM, Trujillo M. Screening for childhood physical and sexual abuse among outpatient substance abusers. Journal of Substance Abuse Treatment. 1994;11(4):347-58. Does not evaluate appropriate intervention. [pmid: 7966505].
299 Sipkoff M. Insurers give substance abuse new identity: it's a disease. Managed Care 14(4):18–20, 23–4, 26, 2005. Exclude, kept for background
300 Smith GC, Clarke DM, Handrinos D. Recognising drug and alcohol problems in patients referred to consultation-liaison psychiatry. Medical Journal of Australia 1995; 163(6):307, 310–302. Does not report designated outcomes
301 Soares BGO, Lima MS, Lima Reisser A, Farrell M. Dopamine agonists for cocaine dependence. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
302 Sofuoglu M, Singha A, Kosten TR, McCance-Katz FE, Petrakis I, Oliveto A. Effects of naltrexone and isradipine, alone or in combination, on cocaine responses in humans. Pharmacol Biochem Behav. Jul. 2003;75(4):801-8. Does not evaluate appropriate intervention. [pmid: 12957222].
303 Sorensen JL, Copeland AL. Drug abuse treatment as an HIV prevention strategy: a review. Drug & Alcohol Dependence. 2000;59(1):17-31. Excluded study design. [pmid: 10706972].
304 Soyka M, Hock B, Kagerer S, Lehnert R, Limmer C, Kuefner H. Less impairment on one portion of a driving-relevant psychomotor battery in buprenorphine-maintained than in methadone-maintained patients: results of a randomized clinical trial. Journal of Clinical Psychopharmacology. 2005;25(5):490-3. Comparative effectiveness. [pmid: 16160628].
305 Srisurapanont M, Jarusuraisin N, Kittirattanapaiboon P. Treatment for amphetamine dependence and abuse. Cochrane Database of Systematic Reviews 2005. Kept for use as source document
306 Stanton MD, Shadish WR. Outcome, attrition, and family-couples treatment for drug abuse: a meta-analysis and review of the controlled, comparative studies. Psychol Bull. 1997;122(2):170-191. Comparative effectiveness. [pmid: 9283299].
307 Stein MD, Anderson B, Charuvastra A, Maksad J, Friedmann PD. A brief intervention for hazardous drinkers in a needle exchange program. J Subst Abuse Treat. 2002;22(1):23-31. Does not report designated outcomes. [pmid: 11849904].
308 Stein MD, Charuvastra A, Maksad J, Anderson BJ. A randomized trial of a brief alcohol intervention for needle exchangers (BRAINE). Addiction. 2002;97(6):691-700. Does not report designated outcomes. [pmid: 12084138].
309 Stella L, D'Ambra C, Mazzeo F, Capuano A, Del Franco F, Avolio A, et al. Naltrexone plus benzodiazepine aids abstinence in opioid-dependent patients. Life Sciences. 2005;77(21):2717-22. Comparative effectiveness. [pmid: 15979652].
310 Stephens RS, Babor TF, Kadden R, Miller M. Marijuana Treatment Project Research Group. The Marijuana Treatment Project: rationale, design and participant characteristics. Addiction. 2002;97(Suppl 1):109-24. Does not report designated outcomes. [pmid: 12460133].
311 Stephens RS, Roffman RA, Curtin L. Comparison of extended versus brief treatments for marijuana use. J Consult Clin Psychol. 2000;68(5):898-908. Excluded for quality. [pmid: 11068976].
312 Sterk CE, Theall KP, Elifson KW, Kidder D. HIV risk reduction among African-American women who inject drugs: a randomized controlled trial. AIDS & Behavior. 2003;7(1):73-86. Does not evaluate appropriate intervention. [pmid: 14534392].
313 Sterk CE, Theall KP, Elifson KW. Effectiveness of a risk reduction intervention among African American women who use crack cocaine. AIDS Education & Prevention. 2003;15(1):15-32. Does not evaluate appropriate intervention. [pmid: 12627741].
314 Stine SM, Krystal JH, Kosten TR, Charney DS. Mazindol treatment for cocaine dependence. Drug Alcohol Depend. 1995;39(3):245-252. Comparative effectiveness. [pmid: 8556974].
315 Stoffel VC, Moyers PA. An evidence-based and occupational perspective of interventions for persons with substance-use disorders. Am J Occup Ther. 2004;58(5):570-586. Excluded study design. [pmid: 15481784].
316 Stoller KB, Bigelow GE, Walsh SL, Strain EC. Effects of buprenorphine/naloxone in opioid-dependent humans. Psychopharmacology. 2001;154(3):230-42. Comparative effectiveness. [pmid: 11351930].
317 Strain EC, Stitzer ML, Liebson IA, Bigelow GE. Methadone dose and treatment outcome. Drug Alcohol Depend. 1993;33(2):105-117. Exclude, kept for background. [pmid: 8261875].
318 Substance Abuse and Mental Health Services Administration. Overview of Findings from the 2004 National Survey on Drug Use and Health. Office of Applied Studies, editor. DUH Series H-27, DHHS Publication No. SMA 05-0461. 2005. Exclude, kept for background
319 Substance Abuse and Mental Health Services Administration. Results from the 2004 National Survey on Drug Use and Health: National Findings. NSDUH series H-28, DHHS Publication No. SMA 05-4062. 2005. Rockville, MD, SAMHSA, Office of Applied Studies. Exclude, kept for background
320 Substance Abuse and Mental Health Services, Office of Applied Studies. National Survey of Substance Abuse Treatment Services (N-SSATS): 2003. Data on Substance Abuse Treatment Facilities. ASIS Series: S-24; DHHS Publication No. (SMA) 04-3966. 2003. Rockville, MD, Office of Applied Studies. Exclude, kept for background
321 Sullivan LE, Metzger DS, Fudala PJ, Fiellin DA. Decreasing international HIV transmission: the role of expanding access to opioid agonist therapies for injection drug users. Addiction. 2005;100(2):150-158. Exclude, kept for background. [pmid: 15679744].
322 Svikis D, Henningfield J, Gazaway P, Huggins G, Sosnow K, Hranicka J, et al. Tobacco use for identifying pregnant women at risk of substance abuse. Journal of Reproductive Medicine. 1997;42(5):299-302. Does not report designated outcomes. [pmid: 9172121].
323 Swedish Council on Technology Assessment in Health Care (SBU). Treatment of alcohol and drug abuse: an evidence-based review. Int J Technol Assess Health Care. 2002;18(1):145-154. Excluded for quality. [pmid: 11987438].
324 Tait RJ, Hulse GK, Robertson SI, Sprivulis PC. Emergency department-based intervention with adolescent substance users: 12-month outcomes. Drug & Alcohol Dependence. 2005;79(3):359-363. Exclude, kept for background. [pmid: 16102378].
325 Tait RJ, Hulse GK. A systematic review of the effectiveness of brief interventions with substance using adolescents by type of drug. Drug & Alcohol Review. 2003;22(3):337-346. Excluded for quality. [pmid: 15385228].
326 Tapert SF, Aarons GA, Sedlar GR, Brown SA. Adolescent substance use and sexual risk-taking behavior. J Adolesc Health. 2001;28(3):181-189. Does not evaluate appropriate intervention. [pmid: 11226840].
327 Tennant FS Jr, Tarver AL. Double-blind comparison of desipramine and placebo in withdrawal from cocaine dependence. NIDA Res Monogr. 1984;55:159-163. Does not evaluate appropriate intervention. [pmid: 6443373].
328 Tian X, Krishnan S. Efficacy of auricular acupressure as an adjuvant therapy in substance abuse treatment: a pilot study. Alternative Therapies in Health & Medicine. 2006;12(1):66-9. Excluded for quality. [pmid: 16454149].
329 Torrens M, Fonseca F, Mateu G, Farre M. Efficacy of antidepressants in substance use disorders with and without comorbid depression. A systematic review and meta-analysis. Drug & Alcohol Dependence. 2005;78(1):1-22. Kept for use as source document. [pmid: 15769553].
330 Tran TN, Detels R, Long HT, Lan HP. Drug use among female sex workers in Hanoi, Vietnam. Addiction. 2005;100(5):619-625. Excluded study design. [pmid: 15847619].
331 Treatment options for opiate addiction. J Ky Med Assoc 2004; 102(5):221–224. Excluded study design
332 Turner BJ, Markson L, Hauck W, Cocroft J, Fanning T. Prenatal care of HIV-infected women: analysis of a large New York State cohort. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1995;9(4):371-378. Does not evaluate appropriate intervention. [pmid: 7600104].
333 U.S.Department of Health and Human Servicies, National Institute of Health, National Institute on Drug Abuse. Drug Addiction Research and the Health of Women. Wetherington C, Roman A, editors. 1998. Exclude, kept for background
334 U.S.Preventive Services Task Force. Screening for Drug Abuse. Guide to Clinical Preventive Services, Second Edition. Lippincott Williams & Wilkins, 1996: 583–594. Exclude, kept for background
335 Ursitti F, Klein J, Koren G. Confirmation of cocaine use during pregnancy: a critical review. Therapeutic Drug Monitoring. 2001;23(4):347-53. Does not evaluate appropriate intervention. [pmid: 11477315].
336 Van Amerongen D. Trying to reach the pregnant substance-abuser: learning from failure. Hmo Practice. 1996;10(2):80-82. Does not report designated outcomes. [pmid: 10172653].
337 van den BW. Medical prescription of heroin to treatment resistant heroin addicts: two randomised controlled trials. BMJ (Clinical research ed) 327;(7410). Comparative effectiveness
338 Vanichseni S, Wongsuwan B, Choopanya K, Wongpanich K. A controlled trial of methadone maintenance in a population of intravenous drug users in Bangkok: implications for prevention of HIV. Int J Addict. 1991;26(12):1313-1320. Non-English. [pmid: 1787024].
339 Vorma H, Naukkarinen H, Sarna S, Kuoppasalmi K. Symptom severity and quality of life after benzodiazepine withdrawal treatment in participants with complicated dependence. Addict Behav. 2004;29(6):1059-1065. Does not report designated outcomes. [pmid: 15236807].
340 Waldron HB, Kaminer Y. On the learning curve: the emerging evidence supporting cognitive-behavioral therapies for adolescent substance abuse. Addiction. 2004;99(Suppl 2):93-105. Comparative effectiveness. [pmid: 15488108].
341 Waldron HB, Slesnick N, Brody JL, Turner CW, Peterson TR. Treatment outcomes for adolescent substance abuse at 4- and 7-month assessments. Journal of Consulting & Clinical Psychology. 2001;69(5):802-13. Comparative effectiveness. [pmid: 11680557].
342 Washington State Department of Health. Substance Abuse During Pregnancy: Guidelines for Screening. Taylor P, Zaichkin J, Bailey D, editors. 2002. Exclude, kept for background
343 Waxmonsky JG, Wilens TE. Pharmacotherapy of adolescent substance use disorders: a review of the literature. Journal of Child & Adolescent Psychopharmacology. 2005;15(5):810-25. Excluded study design. [pmid: 16262597].
344 Weaver GD, Turner NH, O'Dell KJ. Depressive symptoms, stress, and coping among women recovering from addiction. J Subst Abuse Treat. 2000;18(2):161-167. Excluded study design. [pmid: 10716099].
345 Weisner C, Mertens J, Parthasarathy S, Moore C, Lu Y. Integrating primary medical care with addiction treatment: a randomized controlled trial. JAMA. 2001;286(14):1715-23. Comparative effectiveness. [pmid: 11594896].
346 Weiss RD, Griffin ML, Gallop RJ, Najavits LM, Frank A, Crits-Christoph P, et al. The effect of 12-step self-help group attendance and participation on drug use outcomes among cocaine-dependent patients. Drug & Alcohol Dependence. 2005;77(2):177-84. Excluded for quality. [pmid: 15664719].
347 Weiss RD, Najavits LM, Greenfield SF, Soto JA, Shaw SR, Wyner D. Validity of substance use self-reports in dually diagnosed outpatients. American Journal of Psychiatry. 1998;155(1):127-128. Comparative effectiveness. [pmid: 9433351].
348 Weizman T, Gelkopf M, Melamed Y, Adelson M, Bleich A. Cannabis abuse is not a risk factor for treatment outcome in methadone maintenance treatment: a 1-year prospective study in an Israeli clinic. Australian & New Zealand Journal of Psychiatry. 2004;38(12):42-6. Does not evaluate appropriate intervention. [pmid: 14731193].
349 Wells EA, Calsyn DA, Clark LL, Saxon AJ, Jackson TR. Retention in methadone maintenance is associated with reductions in different HIV risk behaviors for women and men. American Journal of Drug & Alcohol Abuse. 1996;22(4):509-521. Does not evaluate appropriate intervention. [pmid: 8911589].
350 Werner MJ, Joffe A, Graham AV. Screening, early identification, and office-based intervention with children and youth living in substance-abusing families. Pediatrics. 1999;103(5):1099-1112. Does not report designated outcomes. [pmid: 10224197].
351 West SL, O'Neal KK, Graham CW. A meta-analysis comparing the effectiveness of buprenorphine and methadone. J Subst Abuse. 2000;12(4):405-414. Comparative effectiveness. [pmid: 11452842].
352 Westermeyer J, Canino G. Culture and Substance Related Disorders. DSM-IV Sourcebook. American Psychiatric Association, 1997. Exclude, kept for background
353 Wickizer T, Maynard C, Atherly A, Frederick M, Koepsell T, Krupski A, et al. Completion rates of clients discharged from drug and alcohol treatment programs in Washington State. Am J Public Health. 1994;84(2):215-221. Does not report designated outcomes. [pmid: 8296943].
354 Wiebel WW, Jimenez A, Johnson W, Ouellet L, Jovanovic B, Lampinen T, et al. Risk behavior and HIV seroincidence among out-of-treatment injection drug users: a four-year prospective study. Journal of Acquired Immune Deficiency Syndromes & Human Retrovirology. 1996;12(3):282-289. Does not evaluate appropriate intervention. [pmid: 8673532].
355 Williams RJ, Chang SY. A comprehensive and comparative review of adolescent substance abuse treatment outcome. Clinical Psychology: Science and Practice. 2000;7(2):138-166. Comparative effectiveness.
356 Wingert WE, Feldman MS, Kim MH, Noble L, Hand I, Yoon JJ. A comparison of meconium, maternal urine and neonatal urine for detection of maternal drug use during pregnancy. Journal of Forensic Sciences. 1994;39(1):150-158. Comparative effectiveness. [pmid: 8113697].
357 Winhusen T, Somoza E, Harrer JM, Moore E, Ussery T, Kropp F, et al. Metyrapone and cocaine: a double-blind, placebo-controlled drug interaction study. Pharmacology, Biochemistry & Behavior. 2005;80(4):631-8. Does not report designated outcomes.
358 Winhusen TM, Somoza EC, Harrer JM, Mezinskis JP, Montgomery MA, Goldsmith RJ, et al. A placebo-controlled screening trial of tiagabine, sertraline and donepezil as cocaine dependence treatments. Addiction. 2005;100(Suppl 1):68-77. Comparative effectiveness. [pmid: 15730351].
359 Wolff K, Farrell M, Marsden J, Monteiro MG, Ali R, Welch S, et al. A review of biological indicators of illicit drug use, practical considerations and clinical usefulness. Addiction. 1999;94(9):1279-1298. Does not report designated outcomes. [pmid: 10615715].
360 Woo C, Reid MS, Leiderman D, Montgomery A, Majewska D, Baker S, Schwartz M, O'Leary S, Duffy M, Conner E, Robinsnon J, Rotrosen J. A clinical trial of celebrex versus placebo for the treatment of cocaine dependence. Drug and alcohol dependence. 2001;Vol 63(Suppl 1):172-1. Comparative effectiveness.
361 Wood E, Spittal P, Li K, Kerr T, Miller CL, Hogg RS, et al. Inability to access addiction treatment and risk of HIV infection among injection drug users. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2004;36(2):750-754. Does not evaluate appropriate intervention. [pmid: 15167295].
362 Woody GE, McLellan AT, Bovasso G, Kurtz J, O'Brien CP. Methadone maintenance and opioid positive urine: a test of 80 mg vs 120 mg and MET vs DC. Drug and alcohol dependence. 2001;Vol 63(Suppl 1):173. Comparative effectiveness.
363 Woody GE, Gallop R, Luborsky L, Blaine J, Frank A, Salloum IM, et al. HIV risk reduction in the National Institute on Drug Abuse Cocaine Collaborative Treatment Study. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2003;33(1):82-87. Does not report designated outcomes. [pmid: 12792359].
364 Yao HY, Wang ZZ, Jiang DL, Sun JF, Niu ZX. Evaluation of the effect of interventions for the female drug abusers. Biomedical & Environmental Sciences. 2002;15(4):341-6. Does not evaluate appropriate intervention. [pmid: 12642991].
365 Ying L, Man Jia Z, Fan Rong L. Acupuncture for opioid dependence. Cochrane Database of Systematic Reviews 2005. Comparative effectiveness
366 Zimmermann P, Muhlig S, Sonntag D, Buhringer G, Wittchen HU. Review on psychotherapeutic interventions for cannabis disorders. Sucht. 2004;50(5):334-342. Kept for use as source document.
367 Zuckerman B, Frank DA, Hingson R, Amaro H, Levenson SM, Kayne H, et al. Effects of maternal marijuana and cocaine use on fetal growth. N Engl J Med. 1989;320(12):762-768. Excluded study design. [pmid: 2784193].