# Appendix E. Quality of Prognosis Studies Criteria^*^ * Created using information from Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med 2006; 144(6):427–437.

Potential Biases
Study Participation
The study sample represents the population of interest on key characteristics, sufficient to limit potential bias to the results.
Study Attrition
Loss to follow-up 9 from sample to study population) is not associated with key characteristics (i.e., the study data adequately represent the sample), sufficient to limit potential bias.
Prognostic Factor Measurement
The prognostic factor of interest is adequately measures in study participants to sufficiently limit potential bias.
Outcome Measurement
The outcome of interest is adequately measured in study participants
Confounding Measurement and Account
Important potential confounders are appropriately accounted for, limiting potential bias with respect to the prognostic factor of interest.
Analysis
The statistical analysis is appropriate for the design of the stud limiting potential for presentation of invalid results.

Note: Response categories were: Yes; Partly; No; or Unsure