# Appendix B. Inclusion and Exclusion Criteria

Key Question 1. Is there direct evidence that screening for drug misuse reduces morbidity and/or mortality?

Inclusion Criteria
Meets criteria for KQ1 and:
[underlined: Drugs:] opiates, cocaine, marijuana, and mixed drugs
[underlined: Study designs:] randomized controlled trials, controlled clinical trials, prospective, and observational studies
[underlined: Publication years:] 1994-present, or earlier years if identified in systematic reviews or the 1996 USPSTF report
[underlined: Populations:] adolescents/teens 12–17, young adults 18–25, adults 26+, or pregnant women
[underlined: Intermediate outcomes:] abstinence, decreased use, time to relapse, risk behaviors, social/legal.
[underlined: Health outcomes:] morbidity (infant outcomes, injuries, medical conditions, mental health disorders, quality of life, STD transmission, utilization, violence/unintentional) and mortality.
[underlined: Conducted in an U.S. applicable country]
[underlined: Primary care feasible or referable:] see end of appendix for definitions
Special populations (e.g., mentally ill; tracked, but not included)
Exclusion Criteria
Does not evaluate direct evidence that screening for drug misuse reduces morbidity and/or mortality
Other drugs besides opiates, cocaine, marijuana, and mixed drugs
Non-humans
Non-English abstract
Setting: Intervention not done in primary care, primary care-feasible, or widely available for primary care referral
Population: Selective population not normally seen in primary care (e.g. patients recruited from ER or other specialty setting who are injured or on drugs and do not represent a general patient population)
Country: Study not conducted in a country applicable to the U.S. population
Outcomes: Does not report designated outcomes
Study quality: Does not meet USPSTF criteria for quality
Study designs: Editorials, letters, non-systematic reviews, case control studies, case studies, comment/opinion, protocol (no data), pilot studies, abstracts only, etc.

Key Questions 4, 5, & 5a. Does treatment for drug misuse among individuals identified through screening improve morbidity and/or mortality? Does treatment for drug misuse among individuals identified through screening result in decreased drug misuse? Does treatment for drug misuse reduce risk behaviors/improve social/legal outcomes?

Inclusion Criteria
Meets criteria for KQs 4, 5, or 5a and:
[underlined: Drugs:] opiates, cocaine, marijuana, and mixed drugs
[underlined: Study designs:] systematic reviews and meta-analyses of randomized controlled trials (RCTs) & controlled clinical trials (CCTs), RCTs, CCTs
[underlined: Publication years:] 1994-present,or earlier years if identified in systematic reviews or the 1996 USPSTF report
[underlined: Populations:] adolescents/teens 12–17, young adults 18–25, adults 26+, or pregnant women
[underlined: Intermediate outcomes:] abstinence, decreased use, time to relapse, risk behaviors, social/legal.
[underlined: Health outcomes:] morbidity (infant outcomes, injuries, medical conditions, mental health disorders, quality of life, STD transmission, utilization, violence/unintentional) and mortality.
[underlined: Conducted in an U.S. applicable country]
[underlined: Primary care feasible or referable:] see end of appendix for definitions
Special population (e.g., mentally ill; tracked, but not included)
Exclusion Criteria
Does not evaluate an intervention targeting drug use, misuse, or abuse
Other drugs besides opiates, cocaine, marijuana, and mixed drugs
Non-English abstract
Non-humans
Setting: Intervention not done in primary care, primary care-feasible or widely available for primary care referral
Population: Selective population not normally seen in primary care (e.g. patients recruited from ER or other specialty setting who are injured or on drugs and do not represent a general patient population
Country: Study not conducted in a country applicable to the US population
Outcomes: Does not report designated outcomes
Study quality: Does not meet USPSTF criteria for quality
Study designs: Studies not identified in systematic reviews, authoritative review, comparative effectiveness studies, editorials, letters, non-systematic reviews, non-comparative studies, case control studies, case studies, comment/opinion, protocol (no data), pilot studies, abstracts only, etc.

Key Question 7. Is decreased use or abstinence following drug misuse reliably associated with reduced morbidity and/or mortality?

Inclusion Criteria
Meets criteria for KQ7 and:
[underlined: Drugs:] opiates, cocaine, marijuana, and mixed drugs
[underlined: Study designs:] randomized controlled trials (RCTs), controlled clinical trials, prospective, and observational studies
[underlined: Publication years:] 1994-present, or earlier years if identified in systematic reviews or the 1996 USPSTF report
[underlined: Populations:] adolescents/teens 12–17, young adults 18–25, adults 26+, or pregnant women
[underlined: Intermediate outcomes:] abstinence, decreased use, time to relapse, risk behaviors, social/legal.
[underlined: Health outcomes:] morbidity (infant outcomes, injuries, medical conditions, mental health disorders, quality of life, STD transmission, utilization, violence/unintentional) and mortality.
[underlined: Applicable countries]
[underlined: Primary care feasible or referable]
Special population (e.g., mentally ill; tracked, but not included)
Exclusion Criteria
Does not evaluate whether decreased use or abstinence following drug misuse reliably associated with reduced morbidity and/or mortality
Other drugs besides opiates, cocaine, marijuana, and mixed drugs
Non-English abstract
Non-humans
Setting: Intervention not done in primary care, primary care-feasible, or widely available for primary care referral
Population: Selective population not normally seen in primary care (e.g. patients recruited from ER or other specialty setting who are injured or on drugs and do not represent a general patient population)
Country: Study not conducted in a country applicable to the US population
Outcomes: Does not report designated outcomes (e.g. withdrawal)
Study quality: Does not meet USPSTF criteria for quality
Study designs: Editorials, letters, non-systematic reviews, non-comparative studies, case control studies, case studies, comment/opinion, protocol (no data), pilot studies, abstracts only, etc.

OVERALL CRITERIA FOR JUDGING IF AN INTERVENTION IS PRIMARY CARE FEASIBLE:

Whom Targeted: Somehow involve individual-level identification of being a patient/in need of intervention
Who Delivered: Usually involve primary care clinicians (physicians in family practice, internal medicine, obstetrics-gynecology, pediatricians, general practitioners), other physicians, nurses, nurse practitioners physician assistants or related clinical staff (dietitians, health educators, others counselors) in some direct or indirect way—or, at least, the intervention would be seen as connected to the health care system by the participant.
How Delivered: To individuals or in small groups (15 or less). Do not involve only or primarily group-level interventions outside the primary care setting to achieve behavioral changes. Generally involve no more than 8 group sessions total and intervention time period is no longer than 12 months.
Where Delivered: Could be delivered anywhere (including via the web, interactive technologies, in the home) if linked to primary care as above.

DEFINITION OF PRIMARY CARE REFERABLE:

In order for an intervention to be feasible for primary care referral, it would need to be conducted as part of a healthcare setting or else be widely available in the community at a national level (such as a car seat fitting station within a hospital).