# Appendix A. Search Strategies

KQ1 Screening

Database: Ovid MEDLINE®

1994 to April 21, 2006

1 Substance Abuse Detection/
2 substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or marijuana abuse/ or opioid-related disorders/ or heroin dependence/ or morphine dependence/ or phencyclidine abuse/ or substance abuse, intravenous/
3 Mass Screening/
4 2 and 3
5 1 or 4
6 health outcome$.ti,ab.
7 health consequences.ti,ab.
8 functional status.ti,ab.
9 health status/
10 health status indicators/
11 “Outcome Assessment (Health Care)”/
12 mo.fs.
13 mortality/
14 quality of life/
15 exp arrhythmia/
16 exp myocardial infarction/
17 cerebral hemorrhage/
18 seizures/
19 exp respiratory tract diseases/
20 depression/
21 exp hepatitis/
22 exp endocarditis, bacterial/
23 exp glomerulonephritis/
24 pulmonary embolism/
25 suicide/
26 suicide, attempted/
27 homicide/
28 pregnancy outcome/
29 pregnancy complications/
30 abruptio placentae/
31 Infant, Premature/
32 Labor, Premature/
33 Premature Birth/
34 fetal growth retardation/
35 weight gain/ and pregnancy/
36 Abnormalities, Drug-Induced/
37 Neonatal Abstinence Syndrome/
38 exp accidents/
39 in.fs.
40 exp “wounds and injuries”/
41 asphyxia/
42 exp “Attention Deficit and Disruptive Behavior Disorders”/
43 exp schizophrenia/
44 exp psychotic disorders/
45 exp mood disorders/
46 exp anxiety disorders/
47 exp personality disorders/
48 exp BRAIN/de, gd [Drug Effects, Growth & Development]
49 exp brain diseases/
50 exp Sexually Transmitted Diseases/
51 Fetal Alcohol Syndrome/
52 exp Sex Offenses/
53 Pregnancy, Unplanned/
54 unplanned pregnanc$.ti,ab.
55 unintended pregnanc$.ti,ab.
56 exp HOMELESS PERSONS/
57 exp Educational Measurement/
58 ACHIEVEMENT/
59 UNDERACHIEVEMENT/
60 Student Dropouts/
61 or/6–60
62 5 and 61
63 limit 62 to english language
64 limit 63 to animals
65 limit 63 to humans
66 64 not 65
67 63 not 66
68 limit 67 to yr=“1994 - 2006”
69 from 68 keep 1–500

KQs 4, 5, & 5a Treatment — Systematic Review Search

Database: Ovid MEDLINE(R); CDSR; DARE; PsycINFO

1994 to November 17, 2005

1 Substance-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
2 Amphetamine-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
3 Cocaine-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
4 Marijuana Abuse/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
5 Opioid-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
6 Heroin Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
7 Morphine Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
8 Phencyclidine Abuse/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
9 Substance Abuse, Intravenous/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
10 Behavior, Addictive/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
11 Substance Abuse Treatment Centers/
12 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11
13 systematic review$.mp.
14 systematic literature review$.mp.
15 meta-analysis.pt.
16 meta-analysis.ti.
17 meta-analyses.ti.
18 metaanalysis.ti.
19 Evidence-Based Medicine/
20 (evidence-based and (guideline$ or recommendation$)).mp.
21 (evidenced-based and (guideline$ or recommendation$)).mp.
22 consensus development conference.pt.
23 health planning guidelines/
24 “cochrane database of systematic reviews”.jn.
25 acp journal club.jn.
26 health technology assessment winchester england.jn.
27 evidence report technology assessment summary.jn.
28 (evidence based dentistry or evidence based mental health or evidence based nursing).jn.
29 clinical evidence.jn.
30 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29
31 12 and 30
32 limit 31 to yr=“1994 - 2006”
33 limit 32 to english language

KQs 4, 5, & 5a Treatment — Bridge Search, Individual Articles

Databases: Ovid MEDLINE(R); PsycINFO

2001 to April 7, 2006

Database: Ovid MEDLINE(R)

Search Strategy:

1 Substance-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
2 Cocaine-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
3 Marijuana Abuse/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
4 Opioid-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
5 Heroin Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
6 Morphine Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
7 Substance Abuse Treatment Centers/
8 Behavior, Addictive/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
9 Substance Abuse, Intravenous/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
10 Substance Withdrawal Syndrome/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
11 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12 Substance-Related Disorders/pc [Prevention & Control]
13 Cocaine-Related Disorders/pc [Prevention & Control]
14 Marijuana Abuse/pc [Prevention & Control]
15 Opioid-Related Disorders/pc [Prevention & Control]
16 Heroin Dependence/pc [Prevention & Control]
17 Morphine Dependence/pc [Prevention & Control]
18 Substance Abuse, Intravenous/pc [Prevention & Control]
19 Behavior, Addictive/pc [Prevention & Control]
20 Substance Withdrawal Syndrome/pc [Prevention & Control]
21 Crack Cocaine/
22 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23 cocaine.ti,ab.
24 marijuana.ti,ab.
25 marihuana.ti,ab.
26 cannabis.ti,ab.
27 opioid.ti,ab.
28 opioids.ti,ab.
29 opiate.ti,ab.
30 opiates.ti,ab.
31 narcotic.ti,ab.
32 narcotics.ti,ab.
33 morphine.ti,ab.
34 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33
35 misus$.ti,ab.
36 abus$.ti,ab.
37 addict$.ti,ab.
38 dependent$.ti,ab.
39 dependence.ti,ab.
40 35 or 36 or 37 or 38 or 39
41 ((cocaine or marijuana or marihuana or cannabis or opioid or opioids or opiate or opiates or narcotic or narcotics or morphine) adj25 (misus$ or abus$ or addict$ or dependent$ or dependence)).ti,ab.
42 22 or 41
43 treat.ti,ab,hw.
44 treated.ti,ab,hw.
45 treating.ti,ab,hw.
46 treatment$.ti,ab,hw.
47 therapy.ti,ab,hw.
48 therapies.ti,ab,hw.
49 43 or 44 or 45 or 46 or 47 or 48
50 42 and 49
51 11 or 50
52 limit 51 to (clinical trial or controlled clinical trial or randomized controlled trial)
53 clinical trials/ or controlled clinical trials/ or randomized controlled trials/
54 double-blind method/ or random allocation/ or single-blind method/
55 random$.ti,ab.
56 53 or 54 or 55
57 51 and 56
58 52 or 57
59 limit 58 to english language
60 limit 59 to humans
61 limit 59 to animals
62 61 not 60
63 59 not 62
64 limit 63 to yr=“2001 - 2006”

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

1 Substance-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
2 Cocaine-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
3 Marijuana Abuse/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
4 Opioid-Related Disorders/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
5 Heroin Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
6 Morphine Dependence/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
7 Substance Abuse Treatment Centers/
8 Behavior, Addictive/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
9 Substance Abuse, Intravenous/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
10 Substance Withdrawal Syndrome/dt, rh, th [Drug Therapy, Rehabilitation, Therapy]
11 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12 Substance-Related Disorders/pc [Prevention & Control]
13 Cocaine-Related Disorders/pc [Prevention & Control]
14 Marijuana Abuse/pc [Prevention & Control]
15 Opioid-Related Disorders/pc [Prevention & Control]
16 Heroin Dependence/pc [Prevention & Control]
17 Morphine Dependence/pc [Prevention & Control]
18 Substance Abuse, Intravenous/pc [Prevention & Control]
19 Behavior, Addictive/pc [Prevention & Control]
20 Substance Withdrawal Syndrome/pc [Prevention & Control]
21 Crack Cocaine/
22 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21
23 cocaine.ti,ab.
24 marijuana.ti,ab.
25 marihuana.ti,ab.
26 cannabis.ti,ab.
27 opioid.ti,ab.
28 opioids.ti,ab.
29 opiate.ti,ab.
30 opiates.ti,ab.
31 narcotic.ti,ab.
32 narcotics.ti,ab.
33 morphine.ti,ab.
34 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33
35 misus$.ti,ab.
36 abus$.ti,ab.
37 addict$.ti,ab.
38 dependent$.ti,ab.
39 dependence.ti,ab.
40 35 or 36 or 37 or 38 or 39
41 ((cocaine or marijuana or marihuana or cannabis or opioid or opioids or opiate or opiates or narcotic or narcotics or morphine) adj25 (misus$ or abus$ or addict$ or dependent$ or dependence)).ti,ab.
42 22 or 41
43 treat.ti,ab,hw.
44 treated.ti,ab,hw.
45 treating.ti,ab,hw.
46 treatment$.ti,ab,hw.
47 therapy.ti,ab,hw.
48 therapies.ti,ab,hw.
49 43 or 44 or 45 or 46 or 47 or 48
50 42 and 49
51 11 or 50
52 limit 51 to yr=“2001 - 2005”

Database: PsycINFO

Search Strategy:

1 Drug Addiction/
2 Drug Abuse/
3 Drug Dependency/
4 Heroin Addiction/
5 Polydrug Abuse/
6 Intravenous Drug Usage/
7 Methadone Maintenance/
8 Drug Withdrawal/
9 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8
10 exp TREATMENT/
11 9 and 10
12 Drug Rehabilitation/
13 cocaine.ti,ab,id,hw.
14 marijuana.ti,ab,id,hw.
15 marihuana.ti,ab,id,hw.
16 cannabis.ti,ab,id,hw.
17 opioid.ti,ab,id,hw.
18 opioids.ti,ab,id,hw.
19 opiate.ti,ab,id,hw.
20 opiates.ti,ab,id,hw.
21 narcotic.ti,ab,id,hw.
22 narcotics.ti,ab,id,hw.
23 morphine.ti,ab,id,hw.
24 heroin.ti,ab,id,hw.
25 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24
26 misus$.ti,ab,id,hw.
27 abus$.ti,ab,id,hw.
28 addict$.ti,ab,id,hw.
29 dependent$.ti,ab,id,hw.
30 dependence.ti,ab,id,hw.
31 26 or 27 or 28 or 29 or 30
32 treat$.ti,ab,id,hw.
33 therapy.ti,ab,id,hw.
34 therapies.ti,ab,id,hw.
35 32 or 33 or 34
36 25 and 31 and 35
37 11 or 12 or 36
38 random$.ti,ab,id,hw.
39 clinical trial$.ti,ab,id,hw.
40 controlled trial$.ti,ab,id,hw.
41 38 or 39 or 40
42 37 and 41
43 limit 42 to english language
44 limit 43 to yr=“2001 - 2006”

KQ7 Reduction/cessation of drug misuse and health outcomes

Database: Ovid MEDLINE®

1994 to April 14, 2006

1 substance-related disorders/ or amphetamine-related disorders/ or cocaine-related disorders/ or marijuana abuse/ or opioid-related disorders/ or heroin dependence/ or morphine dependence/ or phencyclidine abuse/ or substance abuse, intravenous/
2 health outcome$.ti,ab.
3 health consequences.ti,ab.
4 functional status.ti,ab.
5 health status/
6 health status indicators/
7 “Outcome Assessment (Health Care)”/
8 mo.fs.
9 mortality/
10 quality of life/
11 exp arrhythmia/
12 exp myocardial infarction/
13 cerebral hemorrhage/
14 seizures/
15 exp respiratory tract diseases/
16 depression/
17 exp hepatitis/
18 exp endocarditis, bacterial/
19 exp glomerulonephritis/
20 pulmonary embolism/
21 suicide/
22 suicide, attempted/
23 homicide/
24 pregnancy outcome/
25 pregnancy complications/
26 abruptio placentae/
27 Infant, Premature/
28 Labor, Premature/
29 Premature Birth/
30 fetal growth retardation/
31 weight gain/ and pregnancy/
32 Abnormalities, Drug-Induced/
33 Neonatal Abstinence Syndrome/
34 exp accidents/
35 in.fs.
36 exp “wounds and injuries”/
37 asphyxia/
38 exp “Attention Deficit and Disruptive Behavior Disorders”/
39 exp schizophrenia/
40 exp psychotic disorders/
41 exp mood disorders/
42 exp anxiety disorders/
43 exp personality disorders/
44 exp BRAIN/de, gd [Drug Effects, Growth & Development]
45 exp brain diseases/
46 exp Sexually Transmitted Diseases/
47 Fetal Alcohol Syndrome/
48 exp Sex Offenses/
49 Pregnancy, Unplanned/
50 unplanned pregnanc$.ti,ab.
51 unintended pregnanc$.ti,ab.
52 exp HOMELESS PERSONS/
53 exp Educational Measurement/
54 ACHIEVEMENT/
55 UNDERACHIEVEMENT/
56 Student Dropouts/
57 or/2–56
58 quit$.ti,ab.
59 reduc$.ti,ab.
60 recover$.ti,ab.
61 decreas$.ti,ab.
62 abstinen$.ti,ab.
63 abstain$.ti,ab.
64 58 or 59 or 60 or 61 or 62 or 63
65 1 and 57 and 64
66 risk$.mp.
67 cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/ (547819)
68 between group$.mp.
69 66 or 67 or 68
70 65 and 69
71 limit 70 to english language
72 limit 71 to animals
73 limit 71 to humans
74 72 not 73
75 71 not 74
76 limit 75 to yr=“1994 - 2006”