# Reference List

1 U.S.Preventive Services Task Force. Screening for Drug Abuse. Guide to Clinical Preventive Services, Second Edition. Rockville, Maryland: Agency for Healthcare Research and Quality., 1996. Available at http://www.ahrq.gov/uspstf/uspsdrug.htm. .
2 Substance Abuse and Mental Health Services Administration. Results from the 2004 National Survey on Drug Use and Health: National Findings. NSDUH series H-28, DHHS Publication No. SMA 05-4062. 2005. Rockville, Maryland: SAMHSA, Office of Applied Studies.
3 Compton WM, Grant BF, Colliver JD, Glantz MD, Stinson FS. Prevalence of marijuana use disorders in the United States: 1991-1992 and 2001-2002. JAMA. 2004;291(17):2114-2121. [pmid: 15126440].
4 Chasnoff IJ, Anson A, Hatcher R, Stenson H, Iaukea K, Randolph LA. Prenatal exposure to cocaine and other drugs. Outcome at four to six years. Ann N Y Acad Sci. 1998;846:314-328. [pmid: 9668418].
5 Horgan C. Substance Abuse: The Nation's Number One Health Problem. Princeton NJ: The Robert Wood Johnson Foundation, 2001.
6 World Health Organization. World Health Report 2002: Reducing Risks, Promoting Healthy Life. Geneva, Switzerland: World Health Organization, 2002. Available at http://www.who.int/whr/2002/en/. Accesssed January 8, 2008.
7 National Institute on Drug Abuse. Research Report Series, 2004. Cocaine abuse and addiction. Available at www.drugabuse.gov/ResearchReports/Cocaine/Cocaine.html. Accessed January 8, 2008.
8 Mertens JR, Lu YW, Parthasarathy S, Moore C, Weisner CM. Medical and psychiatric conditions of alcohol and drug treatment patients in an HMO: comparison with matched controls. Arch Intern Med. 2003;163(20):2511-2517. [pmid: 14609789].
9 Rayburn WF, Bogenschutz MP. Pharmacotherapy for pregnant women with addictions. Am J Obstet Gynecol. 2004;191(6):1885-1897. [pmid: 15592269].
10 Dube SR, Felitti VJ, Dong M, Chapman DP, Giles WH, Anda RF. Childhood abuse, neglect, and household dysfunction and the risk of illicit drug use: the adverse childhood experiences study. Pediatrics. 2003;111(3):564-572. [pmid: 12612237].
11 McLellan AT, Lewis DC, O'Brien CP, Kleber HD. Drug dependence, a chronic medical illness: implications for treatment, insurance, and outcomes evaluation. JAMA. 2000;284(13):1689-1695. [pmid: 11015800].
12 Hser YI, Hoffman V, Grella CE, Anglin MD. A 33-year follow-up of narcotics addicts. Arch Gen Psychiatry. 2001;58(5):503-508. [pmid: 11343531].
13 American Psychiatric Association. Diagnostic and statistical manual of mental disorders, fourth edition, text revision. 4 ed. Washington DC.: American Psychiatric Association, 2000.
14 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
15 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
16 Furlan AD, Clarke J, Esmail R, Sinclair S, Irvin E, Bombardier C. A critical review of reviews on the treatment of chronic low back pain. Spine. 2001;26(7):E155-E162. [pmid: 11295917].
17 Hayden JA, Cote P, Bombardier C. Evaluation of the quality of prognosis studies in systematic reviews. Ann Intern Med. 2006;144(6):427-437. [pmid: 16549855].
18 Assadi SM, Radgoodarzi R, Ahmadi-Abhari SA. Baclofen for maintenance treatment of opioid dependence: a randomized double-blind placebo-controlled clinical trial. BMC Psychiatry. 2003;3:16. [pmid: 14624703].
19 Fudala PJ, Bridge TP, Herbert S, Williford WO, Chiang CN, Jones K, et al. Office-based treatment of opiate addiction with a sublingual-tablet formulation of buprenorphine and naloxone. N Engl J Med. 2003;349(10):949-958. [pmid: 12954743].
20 Gruber K, Chutuape MA, Stitzer ML. Reinforcement-based intensive outpatient treatment for inner city opiate abusers: a short-term evaluation. Drug Alcohol Depend. 2000;57(3):211-223. [pmid: 10661672].
21 Guo S, Jiang Z, Wu Y. Efficacy of naltrexone hydrochloride for preventing relapse among opiate-dependent patients after detoxification. Hong Kong J Psychiatry. 2001;11(4):2-8. Available at www.hkjpsych.com/journal_file. Accessed January 8, 2008.
22 Johnson RE, Eissenberg T, Stitzer ML, Strain EC, Liebson IA, Bigelow GE. A placebo controlled clinical trial of buprenorphine as a treatment for opioid dependence. Drug Alcohol Depend. 1995;40(1):17-25. [pmid: 8746920].
23 Schwartz RP, Highfield DA, Jaffe JH, Brady JV, Butler CB, Rouse CO, et al. A randomized controlled trial of interim methadone maintenance. Arch Gen Psychiatry. 2006;63(1):102-109. [pmid: 16389204].
24 Bernstein J, Bernstein E, Tassiopoulos K, Heeren T, Levenson S, Hingson R. Brief motivational intervention at a clinic visit reduces cocaine and heroin use. Drug Alcohol Depend. 2005;77(1):49-59. [pmid: 15607841].
25 Arndt IO, Dorozynsky L, Woody GE, McLellan AT, O'Brien CP. Desipramine treatment of cocaine dependence in methadone-maintained patients. Arch Gen Psychiatry. 1992;49(11):888-893. [pmid: 1444727].
26 Avants SK, Margolin A, Holford TR, Kosten TR. A randomized controlled trial of auricular acupuncture for cocaine dependence. Arch Intern Med. 2000;160(15):2305-2312. [pmid: 10927727].
27 Batki SL, Washburn AM, Delucchi K, Jones RT. A controlled trial of fluoxetine in crack cocaine dependence. Drug Alcohol Depend. 1996;41(2):137-142. [pmid: 8809502].
28 Feingold A, Oliveto A, Schottenfeld R, Kosten TR. Utility of crossover designs in clinical trials: efficacy of desipramine vs. placebo in opioid-dependent cocaine abusers. Am J Addict. 2002;11(2):111-123. [pmid: 12028741].
29 Passos SR, Camacho LA, Lopes CS, dos Santos MA. Nefazodone in out-patient treatment of inhaled cocaine dependence: a randomized double-blind placebo-controlled trial. Addiction. 2005;100(4):489-494. [pmid: 15784063].
30 Petrakis IL, Carroll KM, Nich C, Gordon LT, McCance-Katz EF, Frankforter T, et al. Disulfiram treatment for cocaine dependence in methadone-maintained opioid addicts. Addiction. 2000;95(2):219-228. [pmid: 10723850].
31 Copeland J, Swift W, Roffman R, Stephens R. A randomized controlled trial of brief cognitive-behavioral interventions for cannabis use disorder. J Subst Abuse Treat. 2001;21(2):55-64. discussion 65–66. [pmid: 11551733].
32 Marijuana Treatment Project Research Group. Brief treatments for cannabis dependence: findings from a randomized multisite trial. J Consult Clin Psychol. 2004;72(3):455-466. [pmid: 15279529].
33 McCambridge J, Strang J. Deterioration over time in effect of Motivational Interviewing in reducing drug consumption and related risk among young people. Addiction. 2005;100(4):470-478. [pmid: 15784061].
34 Stephens RS, Roffman RA, Curtin L. Comparison of extended versus brief treatments for marijuana use. J Consult Clin Psychol. 2000;68(5):898-908. [pmid: 11068976].
35 Sorensen HJ, Jepsen PW, Haastrup S, Juel K. Drug-use pattern, comorbid psychosis and mortality in people with a history of opioid addiction. Acta Psychiatr Scand. 2005;111(3):244-249. [pmid: 15701109].
36 Fridell M, Hesse M. Psychiatric severity and mortality in substance abusers: a 15-year follow-up of drug users. Addict Behav. 2006;31(4):559-565. [pmid: 15967584].
37 Lucas GM, Cheever LW, Chaisson RE, Moore RD. Detrimental effects of continued illicit drug use on the treatment of HIV-1 infection. J Acquir Immune Defic Syndr. 2001;27(3):251-259. [pmid: 11464144].
38 Bouhnik AD, Carrieri MP, Rey D, Spire B, Gastaut JA, Gallais H, et al. Drug injection cessation among HIV-infected injecting drug users. Addict Behav. 2004;29(6):1189-1197. [pmid: 15236822].
39 Lucas GM, Griswold M, Gebo KA, Keruly J, Chaisson RE, Moore RD. Illicit drug use and HIV-1 disease progression: a longitudinal study in the era of highly active antiretroviral therapy. Am J Epidemiol. 2006;163(5):412-420. Epub January 4, 2006. [pmid: 16394200].
40 Moatti JP, Carrieri MP, Spire B, Gastaut JA, Cassuto JP, Moreau J. Adherence to HAART in French HIV-infected injecting drug users: the contribution of buprenorphine drug maintenance treatment. The Manif 2000 study group. AIDS. 2000;14(2):151-155. [pmid: 10708285].
41 Knowlton AR, Latkin CA, Schroeder JR, Hoover DR, Ensminger M, Celentano DD. Longitudinal predictors of depressive symptoms among low income injection drug users. AIDS Care. 2001;13(5):549-559. [pmid: 11571003].
42 Gossop M, Marsden J, Stewart D, Rolfe A. Patterns of improvement after methadone treatment: 1 year follow-up results from the National Treatment Outcome Research Study. Drug Alcohol Depend. 2000;60(3):275-286. [pmid: 11053762].
43 Shankaran S, Das A, Bauer CR, Bada HS, Lester B, Wright LL, et al. Association between patterns of maternal substance use and infant birth weight, length, and head circumference. Pediatrics. 2004;114(2):e226-e234. [pmid: 15286261].
44 Chasnoff IJ, Griffith DR, MacGregor S, Dirkes K, Burns KA. Temporal patterns of cocaine use in pregnancy. Perinatal outcome. JAMA. 1989;261(12):1741-1744. [pmid: 2918671].
45 National Quality Forum. Evidence-Based Practices to Treat Substance Use Disorder (SUDs). www.qualityforum.org. 3-3-2006.
46 Arndt IO, McLellan AT, Dorozynsky L, Woody GE, O'Brien CP. Desipramine treatment for cocaine dependence. Role of antisocial personality disorder. J Nerv Ment Dis. 1994;182(3):151-156. [pmid: 8113775].
47 Tormey WP, Bruzzi A. Acute psychosis due to the interaction of legal compounds—ephedra alkaloids in ‘vigueur fit’ tablets, caffeine in ‘red bull’ and alcohol. Med Sci Law. 2001;41(4):331-336. [pmid: 11693229].
48 McCambridge J, Strang J. The efficacy of single-session motivational interviewing in reducing drug consumption and perceptions of drug-related risk and harm among young people: results from a multi-site cluster randomized trial. Addiction. 2004;99(1):39-52. [pmid: 14678061].
49 Fudala PJ, Woody GW. Recent advances in the treatment of opiate addiction. Curr Psychiatry Rep. 2004;6(5):339-346. [pmid: 15355756].