# Results

## Drug misuse screening and health outcomes (Key Question 1)

We found no evidence addressing the effects on health outcomes of screening to identify and treat drug misuse among asymptomatic individuals in primary care settings. It should be noted that evidence relevant to this key question would require comparing screened versus unscreened individuals. Evidence derived from a context of universal screening comparing individuals who screened positive for drug misuse with individuals who screened negative would not be considered applicable to this key question.

## Drug misuse treatment: Overview (Key Questions 4/5/5a)

Table 2 summarizes the more detailed evidence in Table 3 about the 17 fair- or good-quality trials that were included in Key Question 4, 5, or 5a. Trials are listed alphabetically by first author, within drug categories defined by the main drug being treated: opiates, opiates and cocaine, cocaine, and cannabis. Some trials reported outcomes for drugs in addition to the main drug under which they are categorized. The 6 trials examining treatments for opiate misuse ^18,^ ^19^ – ^23^ were conducted among a total of 906 patients, primarily addicted to heroin. All were conducted among young adult or adult populations, with the exception of Guo 2001 ^21^ , which included some adolescents. Five of the six opiates treatments were prescription drugs. One treatment was a comprehensive, intensive psychosocial intervention. ^20^ One trial (Bernstein 2005) ^24^ evaluated a counseling intervention to decrease opiate and cocaine use among 1175 primary care patients. Among the six trials of cocaine misuse in 650 patients, ^25^ – ^30^ five tested prescription drug treatments and one ^26^ examined an acupuncture treatment. All were conducted among young adult or adult populations. The four trials of cannabis misuse in 1170 patients ^31^ – ^34^ all involved counseling interventions. All were among young adults and adults, except McCambridge (2004, 2005) ^33^ , which included adolescents. Follow-up periods ranged from immediate post-treatment assessments to 1-year post-intake, but were less than six months in duration in 12 of the 17 trials. None of the trials was conducted among pregnant women. With the important exception of Bernstein et al., ^24^ none was conducted among asymptomatic individuals identified through screening for drug misuse in primary care settings.

Table 2 Summary Table - Randomized Controlled Trials of Drug Treatment (Opiates, Cocaine, and Cannabis) for Young Adults and Adults (KQ 4/5/5a)

| | | | Outcomes
Author/Year Quality | N | Intervention | Follow-up (weeks) | Health (KQ 4) | Drug Use (KQ 5) | | Social/Legal (KQ 5a)
| | | | | Self-report | Biochemical
Opiates
Assadi 2003 ^18^ | 40 | Baclofen | 12 | S (depression) | NS (days used) | NS (UA) | *
Fair
Fudala 2003 ^19^ | 296 | Buprenorphine, Buprenorphine+naloxone | 4 (post-tx) | * | * | S (UA) | *
Fair/good
Gruber 2000 ^20^ | 52 | Comprehensive psycho-social including CBT | 12 | S (depression), NS (anxiety), NS (ASI psych), NS (ASI medical) | S (time to first use), S (ASI drug), S (days used heroin), NS (days used cocaine) | NS (UA heroin), NS (UA cocaine), NS (UA both) | NS (ASI employment), NS (currently employed), NS (days paid work), NS (ASI legal), NS (days illegal activity), NS (ASI family/social)
Fair
Guo 2001^†^ ^21^ | 49 | Naltrexone | 24 | * | S (abstinent), S (average months abstinent) | S (UA) | *
Fair
Johnson 1995 ^22^ | 150 | Buprenorphine | 2 | * | * | S (UA, males), NS (UA, females) | *
Fair-
Schwartz 2006 ^23^ | 319 | Methadone (interim) | 16 | * | S (days used heroin) | S (UA heroin), NS (UA cocaine) | S (ASI legal), S (amount illegal income), S (money spent on drugs)
Fair
Opiates and Cocaine
Bernstein 2005^‡^ ^24^ | 1175 | MI | 24 | * | * | NS (hair, cocaine & opiates), S (hair, cocaine), S (hair, opiates) | *
Good
Cocaine
Arndt 1992 ^25^ | 79 | Desipramine | 12 (post-tx) | NS (ASI medical), NS (days medical problems), S (ASI psych), S (days psych problems), NS (BDI) | NS (ASI drug), NS (days used) | Significant—but favors control (UA) | NS (ASI employment), NS (ASI legal), NS (ASI family/social)
Fair
Avants 2000 ^26^ | 82 | Auricular acupuncture | 8 (post-tx) | * | * | S (UA) | *
Fair
Batki 1996 ^27^ | 32 | Fluoxetine | 2 | NS (depression), NS (anxiety) | NS (days used) | NS (UA), NS (plasma) | *
Fair
Feingold 2002 ^28^ | 180 | Desipramine | 26 | * | * | S (UA) | *
Fair
Passos 2005 ^29^ | 210 | Nefazodone | 10 (post-tx) | NS (depression) | NS (abstinence), NS (days to first relapse) | * | *
Fair-
Petrakis 2000 ^30^ | 67 | Disulfiram | 12 (post-tx) | * | S (frequency), S (quantity) | NS (UA) | *
Fair
Cannabis
Copeland 2001 ^31^ | 229 | CBT + MI, 1 or 6 sessions | 32 | NS (psychiatric symptoms) | NS (days abstinent), S (abstinent past month), S (daily quantity), S (SDS score) | * | S (cannabis-related problems)
Good-
Marijuana Treatment Project 2004 ^32^ | 450 | MET 2 sessions, MET 9 sessions + CBT+ case management | 16 | NS (depression), NS (ASI medical), NS (ASI psych), S (anxiety) | S (% days used), S (period smoked daily), S (amount daily), S (abstinent), S (dependence sx), S (abuse sx) | * | S (ASI employment, only 1 Tx group), S (cannabis-related problems)
Fair
McCambridge 2005^†^ ^33^ | 200 | MI | 52 | * | NS (freq./wk), NS (quant./wk), S (abstinent days/mo.) | * | *
Fair
Stephens 2000 ^34^ | 291 | RPT 28 hours+, other psychosocial 3 hours | 16 | * | S (abstinent past month), S (days used past month), S (frequency daily), S (dependence sx) | * | S (cannabis-related problems)
Fair

* This outcome is not reported for this trial

† Includes teen-aged adolescents

‡ Screened medical clinic population

§ p-values = 0.052, 0.045, 0.050 respectively

+ Additional therapy may have been given to treatment group

ASI=Addiction Severity Index; CBT=Cognitive Behavioral Therapy; MET=Motivational Enhancement Therapy; MI=Motivational Interviewing; NS=Not significant; RPT=Relapse Prevention Therapy; S=Significant difference, favors treatment group; Sx=symptoms; Tx=treatment; UA=Urinalysis

Table 3 Evidence Table - Individual Articles Pertaining to Drug Misuse Treatment (KQ 4/5/5a)

Author, Year | | Target Population
Quality Rating | Key Question | (T, Y, A, P)* | Screened Population (Y/N) | Total Number of Patients | Inclusion Criteria | Exclusion Criteria | Type of Drug(s) Being Treated | Treatment/ Intervention (I) & Control (C) Conditions | Treatment Duration, Longest Follow-up (All Follow-ups) | Results for Health Outcomes^†^ (KQ4) | Results for Drug Use Outcomes^†^ (KQ5) | Results for Social/legal Outcomes^†^ (KQ5a) | Did Outcomes Differ at Earlier Follow-ups? (Y/N) | Comments
Bernstein 2005 ^24^ | 5 | Y, A | Y | 1,175 | Medical visit at “episodic” care center; Speak English or one of 3 other languages; Able to complete basic cognitive function tasks for consent; Self-report cocaine or heroin use in past 30 days | In drug abuse tx; In protective custody | Cocaine | I: Motivational interview, active referrals, written handout of treatment sources, 10-day follow-up call | 6-mos | None | Abstinence (average % negative hair analysis tests, among those positive at intake): | None | NA | Peer-counselor - PC-referable? Patient sample based on “use” rather than diagnoses of abuse or dependence
Good | | | (23,669 screened, 5% pos.) | | | | Opiates | C: Handout of treatment sources | (3-, 6-mos) | | Cocaine:
| | | | | | | | | | | I: 22.3%
| | | | | | | | | | | C: 16.9%
| | | | | | | | | | | Adjusted OR=1.51 (1.01, 2.24),
| | | | | | | | | | | p=.045
| | | | | | | | | | | Opiates:
| | | | | | | | | | | I: 40.2%
| | | | | | | | | | | C: 30.6%
| | | | | | | | | | | Adjusted OR=1.57 (1.00, 2.47)
| | | | | | | | | | | p=.050
| | | | | | | | | | | Both:
| | | | | | | | | | | I: 17.4%
| | | | | | | | | | | C: 12.8%
| | | | | | | | | | | Adjusted OR=1.51 (0.98, 2.26),
| | | | | | | | | | | p=.052
Batki 1996 ^27^ | 4, 5 | Y, A | N | 32 | In specific outpatient tx program for ≥ 2 weeks; Using cocaine | None | Cocaine | I: Fluoxetine | Tx: 12 weeks | HAM-D ns | Biochemical: | None | N | Says 12-week trial, but results only cover first 6 weeks of treatment
Fair | | | | | | | | C: Placebo | Follow-up: took average of weeks 1–6 of tx | HAM-Anxiety ns | Urine ns
| | | | | | | | | | | Plasma ns
| | | | | | | | | | | Mean (SD) days used/week:
| | | | | | | | | | | I: 1.6 (0.4)
| | | | | | | | | | | C: 1.4 (0.3)
| | | | | | | | | | | Ns
Copeland 2001 ^31^ | 4, 5, 5a | Y, A | N | 229 | Age 18+; English-literate; Desire to quit cannabis | Weekly use of drugs other than cannabis; AUDIT > 15 plus alcohol-related social problems; Cannabis tx past 3 mos; Current tx for other substance use problems | Cannabis | I1: 1-session manual-based CBT+MI | Tx: 1–6 weeks | GSI from SCL-90-R | % days abstinent: | % cannabis-related problems endorsed among large list | N
Good | | | | | | | | I2: 6-session manual-based CBT-MI | Longest follow-up: average 8 mos | Mean (SD): | I1: 44.8% | Mean (SD)
| | | | | | | | C: Wait-list | | I1: 0.5 (0.4) | I2: 35.9% | I1: 28.4 (18.6)
| | | | | | | | | | I2: 0.6 (0.3) | C: 29.7% | I2: 23.0 (16.8)
| | | | | | | | | | C: 0.6 (0.4) | NS (p=.09) | C: 39.1 (16.6)
| | | | | | | | | | NS, adjusted pairwise p=.2, .6 | % complete abstinent prior month: | I1, I2<C
| | | | | | | | | | | I1: 17.2% | Adjusted p=.004, <.001
| | | | | | | | | | | I2: 20.8%
| | | | | | | | | | | C: 3.6%
| | | | | | | | | | | I1, I2>C, adjusted pairwise p: .05, .05
| | | | | | | | | | | Daily amount cannabis use
| | | | | | | | | | | Mean (SD)
| | | | | | | | | | | I1: 1.5 (1.2)
| | | | | | | | | | | I2: 1.3 (0.9)
| | | | | | | | | | | C: 1.8 (1.0)
| | | | | | | | | | | I1 vs. C, NS;
| | | | | | | | | | | I2<C adjusted p=.02
| | | | | | | | | | | SDS score
| | | | | | | | | | | Mean (SD)
| | | | | | | | | | | I1: 7.6 (4.4)
| | | | | | | | | | | I2: 5.8 (4.3)
| | | | | | | | | | | C: 9.2 (3.2)
| | | | | | | | | | | I1, I2<C adjusted p=.01
Johnson 1995 ^22^ | 5 | Y, A | N | 150 | Urine negative for methadone and positive for opiates; Age 18–50; Negative pregnancy test; No major medical illness; No chronic conditions; No history of serious psychological illness; Met federal guidelines for methadone tx; DSM-III-R criteria for opioid dependence; No prior drug abuse tx with buprenophine; 3 mos since last tx at clinic | None | Opiates | I1: 2-mg buprenorphine | Tx: This study takes place after 2 weeks of tx | None | % of positive urines | None | N | Only have outcomes at end of 2^nd^ week of treatment
Fair | | | | | | | | I2: 8-mg buprenorphine | 2 weeks | | Males:
| | | | | | | | C: Placebo | | | I1: ~70%
| | | | | | | | | | | I2: ~65%
| | | | | | | | | | | C: ~95%
| | | | | | | | | | | I1, I2< C,
| | | | | | | | | | | P<.05
| | | | | | | | | | | Female:
| | | | | | | | | | | I1: 90%
| | | | | | | | | | | I2: ~88%
| | | | | | | | | | | C: 99%
| | | | | | | | | | | P= ns
Gruber 2000 ^20^ | 4, 5, 5a | Y, A | N | 52 | Positive opiate toxicology screen at detox admission; Ages 18–50; Unemployed or employment that would not interfere with tx schedule | History of psychotic sx; Reporting risk of suicide; Medical problems that would interfere with program participation; Enrolled in methodone or other outpatient drug-free tx program; Pregnant women | Opiates | I: Needs assessment, drug-free housing if needed; 2-wk daily 6-hr tx schedule including 1-on-1 CBT counseling, social skills training, job club, recreational activity; approximately $400 per patient in abstinence-contingent support for housing, food, transportation; Abstinence-contingent participation in therapeutic social and recreational activities | Tx: 3-mos | BDI: | Days to first use of either heroin or cocaine: | ASI-Employ: | Y | Small N and unable to randomly assign 5 patients, post-tx assessment; but otherwise good quality study
Fair | | | | | | | | C: Referral to community tx resource | Assessment: 3-mos post-intake | I: 12.9 | I: longer time to first use than C, survival analysis p=.05 | I: .78 | Heroin use I<C at 1 mo
| | | | | | | | | | C: 17.3 | ASI-Drug composite score: | C: .85
| | | | | | | | | | p=.05 for repeated-measures group effect, P=ns for group × time interaction | I: 0.14 | P=ns
| | | | | | | | | | State-Trait Anxiety Index: | C: 0.20 | Curr employed:
| | | | | | | | | | I: 37.6 | Group effect p=.05, | I: 39%
| | | | | | | | | | C: 43.2 | Group*time interaction p=.02 | C: 21%
| | | | | | | | | | P=ns | Days heroin use, past mo: | P=ns
| | | | | | | | | | ASI-Psychological: | I: 8.6 | Days paid work:
| | | | | | | | | | I: .04 | C: 11.3 | I: 8.3
| | | | | | | | | | C: .01 | Group effect p=.05 | C: 7.1
| | | | | | | | | | P=ns | Days cocaine use past mo: | P=ns
| | | | | | | | | | ASI-Medical: | I: 5.7 | ASI-Legal:
| | | | | | | | | | I: 0.19 | C: 4.4 | I: 0.12
| | | | | | | | | | C: 0.31 | ns | C: 0.12
| | | | | | | | | | P=ns | %Abstinent, SR verified by UA, past 30 days: | P=ns
| | | | | | | | | | | Heroin: | Days illegal activity:
| | | | | | | | | | | I: 32% | I: 5.1
| | | | | | | | | | | C: 21%, p=ns | C: 1.0
| | | | | | | | | | | Cocaine: | P=ns
| | | | | | | | | | | I: 29% | ASI: Family-social
| | | | | | | | | | | C: 17% p=ns | I: 0.08
| | | | | | | | | | | Both: | C: 0.06
| | | | | | | | | | | I: 29% | P=ns
| | | | | | | | | | | C: 12.5%, p=ns
Stephens 2000 ^34^ | 5, 5a | Y, A | N | 291 | Used cannabis ≥ 50 times in past 90 days | Alcohol or other drug abuse; Severe psychological distress; Involved in other formal tx for cannabis abuse | Cannabis | I1: 14 2-hr relapse prevention group plus optional 4-session group for support ppl | 4-mo (longest w control group) | None | % Abstinent past month: | # Cannabis-related problems: | N | Used 4-month outcomes because no control group after that
Fair | | | | | | | | I2: 2 90-min session modeled after Miller's Drinker's Check-up, invited to bring support person to 2^nd^ session | (1,4 mos) | | I1: 37% | I1: 3.5 (4.2)
| | | | | | | | C: Delayed tx | | | I2: 37% | I2: 3.3 (4.0)
| | | | | | | | | | | C: 9% | C: 7.9 (4.2)
| | | | | | | | | | | I1, I2>C, p<.001 | I1, I2,C p=.001
| | | | | | | | | | | Days of use/month:
| | | | | | | | | | | Mean (SD)
| | | | | | | | | | | I1: 6.7 (9.9)
| | | | | | | | | | | I2: 7.9 (11.0)
| | | | | | | | | | | C: 17.1 (10.7)
| | | | | | | | | | | I1,I2<C
| | | | | | | | | | | p<.001
| | | | | | | | | | | Times/day (ordinal scale):
| | | | | | | | | | | I1: 1.2 (1.1)
| | | | | | | | | | | I2: 1.2 (1.2)
| | | | | | | | | | | C: 2.0 (1.1) I1, I2<C
| | | | | | | | | | | P<.001
| | | | | | | | | | | # Dependence-related symptoms:
| | | | | | | | | | | I1:2.0 (2.7)
| | | | | | | | | | | I2: 1.9 (2.7)
| | | | | | | | | | | C: 4.6 (2.6)
| | | | | | | | | | | I1, I2<C, P<.001
Arndt 1992 ^46^ | 4, 5, 5a | Y, A | N | 79 | Stable condition in VA MMT; Urine sample positive for cocaine; Age 20–50; DMS-III diagnosis of cocaine abuse last ≥ 3 mos | Medical condition contra-indicating desipramine | Cocaine | I: MMT with extensive services plus desipramine | Tx: 12 weeks | ANCOVA (Group differences): | ANCOVA (Group differences): | ANCOVA (Group differences): | Y - 2 psychological symptom measures favored I at 3-mos follow-up | Male only, in MMT
Fair | | | | | | | | C: MMT with extensive services plus placebo | Follow-up: 6 mos | ASI-medical, days medical problems, ns; | ASI drug, ns; | ASI employment, ns;
| | | | | | | | | | ASI psychiatric, s; | % Cocaine positive, UA: | ASI legal, ns;
| | | | | | | | | | # days psych problems, s; | I: 78% | ASI family/social, ns
| | | | | | | | | | BDI, ns | C: 36%
| | | | | | | | | | | P<0.05 favoring control
Feingold 2002 ^28^ | 5 | Y, A | N | 109 | Age 20–53; opiate-dependent; used cocaine ≥ 1 time in past week plus positive urine test in past month; completed ≥ 16 weeks treatment | History of psychosis; current alcohol or sedative dependence; currently suicidal; current use of prescribed psychoactive medications; significant medical condition; illiteracy; prior buprenorphine tx | Cocaine | I1: Maintained on methadone | 26-weeks | None | Main effect of desipramine significant (p<.001) | None | N | Sample of people in MMT or BMT
Fair | | | | | | | | I2: Maintained on buprenorphine | | | Possible carry-over effects (group getting desipramine first may have maintained when switched to placebo)
| | | | | | | | In each group, half received desipramine for 7 weeks, and then placebo for 7 weeks
Passos 2005 ^29^ | 4,5 | Y, A | N | 210 | Age 18–65; DSM-IV or ICD-10 diagnosis of cocaine dependence | Psychotic/ cognitive impairment diagnosis; external contingencies that could influence reliability of self-report (e.g., probation); health condition that precluded nefazodone; woman of child-bearing age not on birth control; using terfenadine or astemizole; suicidal ideation; epilepsy; used MAO-Is or other psychotropic medications in past 15 days; crack or injectable cocaine users | Cocaine | I: Nefazodone (plus other tx modalities offered) | NR Did “comparison of end-points”, presumably covering 10-week treatment period, most of which dropped out before 10 weeks | ≥ 50% reduction on HAM-D: | ≥ 3 weeks abstinence: | None | N | Brazil
Fair | | | | | | | | C: Placebo (plus other tx modalities offered) | | I: 60.7% | I=49.5%
| | | | | | | | | | C: 50.8% | C=45.7%
| | | | | | | | | | (p=.14) | p=.58
| | | | | | | | | | | Days to first relapse:
| | | | | | | | | | | I=28.9 (2.4)
| | | | | | | | | | | C=25.6 (2.4)
| | | | | | | | | | | p=.39
Marijuana Treatment Project 2004 ^32^ | 4, 5, 5a | Y, A | N | 450 | Age 18+, DSM-IV diagnosis current marijuana dependence, used cannabis 40 of past 90 days | Unwilling to accept random assignment; legal status might have interfered with tx; current DMS-IV diagnosis of dependence on another drug or alcohol; need for immediate medical or psychological tx that precluded randomization; currently in tx or self-help group; inability to provider contact person | Cannabis | I1: 2-session MET | Tx: 5 weeks or 9 weeks | BDI, ASI-Med, ASI-Psych all ns; | % Days smoking, Mean (sd): | ASI-Employment I2< I1, C, p<.05 | N | Variety of recruitment sources, including self-referral, referral from medical doctors, social services, etc.
Fair | | | | | | | | I2: 9-session MET+CBT+Case management | Follow-up: 4-mos | State-Trait Anxiety Inventory-State Form I2< I1, C, p<.01 | I1: 55.9 (36.2) | Marijuana Problems Scale, I1, I2 < C, p<.001
| | | | | | | | C: Delayed tx | (4-, 9-, 15-mo follow-up, but only 4 had control condition) | | I2: 36.2 (38.8)
| | | | | | | | | | | C: 75.6 (30.9)
| | | | | | | | | | | p<.001
| | | | | | | | | | | Periods smoked/day, Mean (sd):
| | | | | | | | | | | I1: 1.4 (0.9)
| | | | | | | | | | | I2: 1.0 (1.1)
| | | | | | | | | | | C: 2.0 (1.1)
| | | | | | | | | | | P<.001
| | | | | | | | | | | Joints per day
| | | | | | | | | | | I1: 1.5 (1.6)
| | | | | | | | | | | I2: 1.0 (1.7)
| | | | | | | | | | | C: 2.0 (1.9)
| | | | | | | | | | | p<.05
| | | | | | | | | | | % Abstinent past 90 days:
| | | | | | | | | | | I1: 8.6%
| | | | | | | | | | | I2: 22.6%
| | | | | | | | | | | C: 3.6%
| | | | | | | | | | | P<.001
| | | | | | | | | | | Dependence symptoms, Mean (sd):
| | | | | | | | | | | I1: 3.7 (2.3)
| | | | | | | | | | | I2: 2.5 (2.3)
| | | | | | | | | | | C: 4.4 (1.9)
| | | | | | | | | | | p<.001
| | | | | | | | | | | Abuse symptoms, Mean (sd):
| | | | | | | | | | | I1: 1.4 (1.1)
| | | | | | | | | | | I2: 1.0 (1.0)
| | | | | | | | | | | C: 1.6 (1.0)
| | | | | | | | | | | p<.001
McCambridge 2004, 2005 ^33,^ ^48^ | 5 | T, Y | N | 200 | Age 16–20; weekly cannabis or stimulant use within previous 3mos | Opiate use; injecting drug use | Cannabis | I: Motivational interview | Tx 1-session | None | Frequency of use/week (95% CI): | None | Y, cannabis use significantly lower in tx group at 3-mo | Mainly peer recruitment
Fair | | | | | | | | C: “Education as usual,” no study-provided information or tx | Follow-up 12-mo | | I: 8.6 (5.8, 11.5)
| | | | | | | | | (3-, 12-mo) | | C: 11.9 (7.4, 16.4), p= ns
| | | | | | | | | | | Quantity of use/week (95% CI):
| | | | | | | | | | | I: 0.21 (0.14, 0.27)
| | | | | | | | | | | C:0.30 (0.17, 0.42) p=ns
| | | | | | | | | | | Abstinent days/mo (95% CI):
| | | | | | | | | | | I: 17.8 (15.6, 20.0)
| | | | | | | | | | | C: 13.7 (11.1, 16.3), p=.025
Assadi 2003 ^18^ | 4, 5 | Y, A | N | 40 | Age 18–60; opiate dependence per DSM-IV; detoxed at specified facility | Pregnant or lactating; clinically serious unstable medical condition; receiving other medications; history of psychosis, mania, or severe depression; concurrent dependency on alcohol, cocaine, hallucinogens; diagnosis of antisocial personality disorder; mentally retarded | Opiate | I: Baclofen | Tx: 12-weeks | I-group showed greater improvement in HAM-D (p<.001) | No differences on % opiate-positive urine samples (I=76.9%, C=75.8%) | None | N | Conducted in Iran, also only included those seeking detox at specific facility
Fair | | | | | | | | C: Placebo | Follow-up: 12 weeks max | | Also no differences on days/week using opiates, opiate craving score, opiate withdrawal score
Avants 2000 ^26^ | 5 | Y, A | N | 82 | Age 18+; Enrolled in MMT; DSM-IV diagnosis of cocaine dependence; evidence of recent cocaine use (positive urine screen or self-report) | Dependence on any other substance than opiates, cocaine, or nicotine; current tx for cocaine dependence; current use of psychotropic medications unless used for > 90 days; use of acupuncture in past 30 days; actively suicidal or psychotic | Cocaine | I1: Auricular acupuncture | Tx: 8 weeks | None | % Positive urine samples per week, analyzed longitudinally: | None | N | Only included ITT analysis because those dropping out had higher prop of positive urine tests, so completers are a biased group.
Fair | | | | | | | | C1: Needle-insertion control | Follow-up: up to 8 weeks | | I1 fewer pos samples than C1 or C2 (p=.01 for repeated measures test of similarity of intercept and slope, p=.01 for I vs C1, p=.05 for I vs C2
| | | | | | | | C2: Relaxation training (no needles)
Fudala 2003 ^19^ | 5 | Y, A | N | 296 | Ages 18–59; DSM-IV diagnosis opiate dependence; seeking opiate-substitution pharmaco-therapy | Pregnant or nursing; medical condition making participation hazardous; aspartate or alanine aminotransferase levels > 3 times upper limit of normal; current primary Axis I DSM-IV diagnosis other than opiate, caffeine, or nicotine dependence; use of methadone, levomethadyl acetate, or naltrexone within 14 days of enrollment | Opiates | I1: Buprenorphine alone | Tx: 4-week | None | % Negative urine tests: | None | N | Recruited from ppl seeking opiate-substitution pharmacotherapy
Fair | | | | | | | | I2: Buprenorphine + naloxone | Followup: 4-week | | I1: 20.7%
| | | | | | | | C: Placebo | | | I2: 17.8%
| | | | | | | | | | | C: 5.8%
| | | | | | | | | | | I1, I2 > C, p<.001
| | | | | | | | | | | Clinician rating of patient functioning:
| | | | | | | | | | | I1, I2>C, p<.001
Schwartz 2006 ^23^ | 5, 5a | A | N | 319 | 1 year of meeting DSM-IV criteria for opiate dependence | Pregnant; acute medical or psychiatric illness | Opiates | I: Interim tx while awaiting admission to MTP; orientation to MTP, physical exam, methadone under direct observation for up to 120 days | Tx: up to 4 mos | None | % with urine tests positive for opiates: | ASI-legal, group × time interaction (p<.001) | N | Recruited from people seeking methadone tx at community tx program
Fair | | | | | | | | C: Wait list for study MTP, plus information on access to other MTPs in area | Follow-up: up to 4 mos | | I: 57% | Amount of money spent on drugs, past 30 days
| | | | | | | | | | | C: 79% | I: $76
| | | | | | | | | | | p<.001 | C: $560
| | | | | | | | | | | # days used heroin, past 30 days: | (p<.001)
| | | | | | | | | | | I: 4.2 (8.6) | Amount of illegal income in past 30 days
| | | | | | | | | | | C: 26.4 (8.8) | I: $36
| | | | | | | | | | | p<.001 | C: $412
| | | | | | | | | | | % with urine tests positive for cocaine: | (p<.02)
| | | | | | | | | | | I: 62%
| | | | | | | | | | | C: 63%
| | | | | | | | | | | p=.85
Guo 2001 ^21^ | 5 | T, Y, A | N | 49 | DSM-IV diagnosis of opiate dependence; successfully completed detox for ≥ 7 days; urine test negative for morphine; patients had “strong desire to abstain from opiates”; accept naltrexone as tx; had relative or friend who guaranteed to supervise patients tx | Receiving tx for opiates; acute withdrawal diagnosis; apparent withdrawal after naloxone challenge test; allergic to naltrexone; severe physical or mental disease | Opiates | I: Naltrexone | Tx: 6 mos | None | % Abstinent at 6-mo: | None | N | Set in China, required relative/friend to supervise taking medications
Fair | | | | | | | | C: Placebo | Follow-up: 6 mos | | I: 31.4%
| | | | | | | | | (1-, 2-, 3-, 4-, 5-, 6-mo) | | C: 7.1%
| | | | | | | | | | | p<.05
| | | | | | | | | | | Average mos abstinent:
| | | | | | | | | | | I: 3.3 (2.3)
| | | | | | | | | | | C: 2.1 (1.6)
| | | | | | | | | | | p<.05
| | | | | | | | | | | % Positive urine samples:
| | | | | | | | | | | I: 24.4%
| | | | | | | | | | | C: 40.5%
| | | | | | | | | | | p<.05
Petrakis 2000 ^30^ | 5 | A | N | 67 | Enrolled in MMT for opiate dependence for ≥ 3 mos.; cocaine dependence; current use of cocaine | Psychotic or bipolar disorders, serious psychiatric symptoms, medical problems that would contraindicate disulfiram; pregnant | Cocaine | I: Disulfiram 250 mg/day (n=36) | Tx: 3-mos; | None | Random effects regression: | None | NA | Small sample, MMT patients; 52% female increases generalizability among this population, but no follow-up interval after treatment end, and results NS when based on urinalysis
Fair | | | | | | | | C: Placebo (n=31) | Folow-up at post-tx only | | Group × time, frequency of cocaine use (p=0.04); quantity of cocaine use (p=0.02) based on self-report; results NS when based on UA.
| | | | | | | | (Both medications dissolved in methadone dose) | | | Self-reported days cocaine use in past 30, mean (SD):
| | | | | | | | | | | Pre-tx:
| | | | | | | | | | | I: 19.65 (9.86)
| | | | | | | | | | | C: 16.74 (9.78)
| | | | | | | | | | | Post-tx:
| | | | | | | | | | | I: 4.96 (7.50)
| | | | | | | | | | | C: 6.68 (7.03)
| | | | | | | | | | | Self-reported grams cocaine used weekly in past 30 days, mean (SD):
| | | | | | | | | | | Pre-tx:
| | | | | | | | | | | I: 3.16 (5.07)
| | | | | | | | | | | C: 1.46 (1.92)
| | | | | | | | | | | Post-tx:
| | | | | | | | | | | 0.59 (1.28)
| | | | | | | | | | | 0.41 (0.51)

* Populations include: T, Teens; Y, Young adults; A, Adults; P, Pregnant Women.

† Results at longest follow-up assessment

ASI=Addiction Severity Index; AUDIT=Alcohol Use Disorders Identification Test; CBT=Cognitive Behavioral Therapy; GSI=General Severity Index; SCL-90-R=Symptom Checklist- 90-Revised; HAM-D=Hamilton Depression Rating Scale; MI=Motivational Interviewing; MET=Motivational Enhancement Therapy; MTP=Methadone Treatment Program; NR=Not reported; Ns=Not significant; RBT=Reinforcement-based Intensive Outpatient Treatment; RPT=Relapse Prevention Therapy; S=Significant; SDS=Severity of Dependence Scale; Sx,=Symptoms; Tx=Treatment; UA=Urinalysis.

### Drug misuse treatment and health outcomes (Key Question 4)

Fewer than half of the trials in Table 2 reported mental or physical health outcomes after drug misuse treatment. Two of these were opiate trials, ^18,^ ^20^ three were cocaine trials ^25,^ ^27,^ ^29^ and two were cannabis trials (Table 2, column 5). Follow-up periods were 4 months or less, and health outcomes were measured by indices of mental or physical health symptoms, rather than diagnosed health conditions. Assadi et al., ^18^ in a trial of baclofen treatment of opiate dependence, found a significant reduction in depression symptoms in the treatment group at 3 months (although there was no difference in opiate use). Gruber et al. ^20^ found that a comprehensive psychosocial intervention reduced depressive symptoms, but not anxiety symptoms, a general index of psychiatric severity, or a general index of physical health at 3-month follow-up. Trials of cocaine misuse treatments reported mostly non-significant results for health outcomes. While desipramine was shown in one trial ^25^ to improve two indices of psychiatric severity, it did not improve depressive symptoms or cocaine use. Of the two cannabis trials, one reported an improvement in anxiety, but not other psychiatric or medical symptoms, using a motivational enhancement counseling intervention, ^32^ and the other reported no effect of combined cognitive-behavioral and motivational counseling on a general index of psychiatric symptoms. ^31^

#### Summary of Key Question 4

The evidence summarized in Table 2 provides little indication that drug misuse treatment improves health outcomes. Most trials did not report health outcomes. None of the evidence came from trials of asymptomatic individuals who were identified through screening for drug misuse in primary care. There was no representation of adolescent or pregnant female populations.

### Drug misuse treatment, drug use, and social or legal outcomes (Key Questions 5/5a)

All of the trials in Table 2 reported drug use outcomes, often including both self-reported and biochemical (usually urinalysis) measures of use. These trials provide good evidence that several drugs (methadone, buprenorphine, and naltrexone) reduce opiate use, at least in the short-term. One intensive, psychosocial intervention also reduced heroin use at 3-month follow-up according to self-reports, but not according to urinalysis. Auricular acupuncture ^26^ and desipramine ^28^ reduced cocaine use when measured by urinalysis at post-treatment assessments, while disulfiram ^30^ reduced self-reported, but not biochemically-verified, cocaine use. The three cannabis treatment trials among young adults or adults reduced multiple self-reported measures of cannabis use. Results from the one cannabis trial including adolescents ^33^ were inconsistent, but nonetheless found significantly more days abstinent in the treatment group. None of the cannabis trials reported separate biochemical measures of drug use outcomes, although some reported high levels of agreement between self-report and urinalysis results (e.g., Marijuana Treatment Project ^32^ ). The largest single trial ^24^ tested a motivational counseling intervention conducted by former drug users to reduce opiate and/or cocaine use among 1175 patients in an outpatient medical clinic. Based on analyses of hair samples, the intervention reduced cocaine use and opiate use at 6-month follow-up. Results for combined cocaine and opiate use were marginally non-significant (p=0.052). Bernstein et al. recruited participants by screening asymptomatic primary care patients for opiate or cocaine use, making this trial unique among those in our review.

Only six trials reported intermediate social and legal outcomes. Gruber et al. ^20^ reported no effects of their psychosocial intervention for opiate misuse on any of several measures of employment, illegal activity, or social functioning at 3-month follow-up. Interim methadone treatment (i.e., during a waiting period before slots in existing methadone treatment programs were available) did significantly reduce illegal activity and the amount of money spent on drugs during a 4-month follow-up period. One cocaine trial (of desipramine treatment) found null results on indicators of employment, illegal activity, and social functioning. ^25^ Three of the cannabis trials reported significant improvements in cannabis-related problems, ^31,^ ^32,^ ^34^ and one of these also reported improvement in an employment index. ^32^

#### Summary of Key Questions 5/5a

Overall, the evidence in Table 2 indicates that various drug misuse treatments—including pharmacotherapies and behavioral interventions—effectively reduce opiate, cocaine, or marijuana misuse (KQ5). Follow-up periods were typically short, however, rarely being longer than 6 months after intake. All trials were conducted among treatment-seeking, instead of screened, populations, with one exception ^24^ in which a brief intervention reduced cocaine and opiate use among primary care patients identified through screening for use of these substances. Evidence of treatment effects on other intermediate outcomes was sparser and less consistent, although behavioral counseling interventions for cannabis misuse appear to reduce cannabis-related problems.

## Health benefits of decreasing or ceasing drug misuse (Key Question 7)

Nine of the eleven studies which were identified as relevant to the health benefits of cessation or reduced drug use examined opiate, cocaine, or multiple drug misuse among young adult or adult populations, while two addressed cocaine or cannabis misuse among pregnant women (see Table 4). None directly studied adolescent populations. Among the nine studies of young adults or adults, follow-up periods ranged from 6 months (two studies) to 33 years (one study). Injecting drugs was a frequent route of administration (five studies; route not reported or in four studies). Health outcomes in these studies included mortality, indices of physical and/or mental health and functioning, participation in highly active anti-retroviral therapy (HAART), and HIV disease progression in HAART patients. None of the studies was conducted among screened primary care populations.

Table 4 Evidence Table - Relationships Between Stopping or Reducing Drug Misuse and Morbidity or Mortality Outcomes (KQ 7)

Author, Year | | Target Population
Quality Rating | Study Design | (T,Y,A,P) | Screened Pop.? (Y/N) | Total Number of Patients | Inclusion Criteria, Sample Description | Exclusion Criteria | Type of Drug(s) | Groups Analyzed | Length of Follow-up | Type of Analysis | Outcome(s) | Results^†^ | Reviewer Comment
Sorensen 2005 ^35^ | Prospective Cohort | A | N | 300 at intake; | Copenhagen, Denmark. | Died before 1984 (n=78), non-response to interview attempt in 1984 (n=34) | Opiates (Heroin, morphine) | Based on drug status in 1984:; 1 Stable drug-free abstinent (n=87);; 2 Occasional illegal drug use or in MMT (n=53);; 3 Daily (illegal) drug use or daily injection drug use (may have also included alcohol or other drug use) (n=48) | 15 yr (1984-99) | 1 Survival analysis (Cox proportional hazards); 2 Comparison with sex-specific standard mortality ratios (SMR) for Danish population | Mortality, SMR | 1. Hazard rate (95% CI): | 3 time points, allows inference from drug misuse cessation to subsequent reduction in mortality
Fair | | | | 188 interviewed in 1984 | Treated for opioid addiction in 1973 | | | | | | | Group 1:
| | | | | | | | | | | | 0.45 (0.2, 0.8);
| | | | | | | | | | | | Group 2:
| | | | | | | | | | | | 0.74 (0.4, 1.4)
| | | | | | | | | | | | Group 3: ref.
| | | | | | | | | | | | (adjusted for age, gender, psychosis hospitalization)
| | | | | | | | | | | | 2. Sex-specific SMRs (95% CI):
| | | | | | | | | | | | Women
| | | | | | | | | | | | Group 1:
| | | | | | | | | | | | 7 (2.4, 17.0)
| | | | | | | | | | | | Group 2:
| | | | | | | | | | | | 22 (8.2, 48.8)
| | | | | | | | | | | | Group 3:
| | | | | | | | | | | | 34 (15.7, 65.1)
| | | | | | | | | | | | Men
| | | | | | | | | | | | Group 1:
| | | | | | | | | | | | 8 (4.6, 13.6)
| | | | | | | | | | | | Group 2:
| | | | | | | | | | | | 11 (5.9, 19.0)
| | | | | | | | | | | | Group 3:
| | | | | | | | | | | | 13 (6.7, 21.6)
Hser 2001 ^12^ | Prospective cohort, some cross-sectional analyses | Y, A | N | 581 at intake; | Male criminal offenders, mandated to opioid treatment in 1962-64 | NR | Heroin | 1 For mortality analysis: Current heroin users vs. non-users, at 2 interview points: 1974-75 & 1985-86; 2 For health outcomes among 242 interviewed in 1996-97: | For mortality: 2 10-yr intervals (at 1996-97 and 1985-86 fups) | Multiple logistic regression: 1974-75 & 1985-86 heroin use status to predict mortality by 1985-86 & 1996-97, respectively. | 1 Mortality; 2 Physical & mental health status:; a) disability; b) hepatitis; c) HIV; d) STD's; e) depression; f) anxiety; g) somatization disorder; h) OCD; i) interpersonal sensitivity | 1. Active heroin status (yes vs. no): | Long-term fup, 3 time points are strengths; criminally-involved, male sample limits generalizability; cross-sectional results for morbidity outcomes
Fair | | | | 242 interviewed in 1996-97: 284 dead, 31 refused, 24 lost to fup | | | | persons abstinent >= past 5 yr (n=113) vs. current users or abstinent < past 5 yr | Cross-sectional for other health outcomes | Adj. for race, age, disability status, cigarette smoking, heavy alcohol use, years since first heroin use, arrests since previous interview | | 1974-75 to 1985-86 (n=439):
| | | | | | | | (n=129) | | | | Adj. OR (95% CI) = 1.32 (0.75–2.35)
| | | | | | | | | | | | 1985-86 to 1996-97 (n=345):
| | | | | | | | | | | | 1.38 (0.76–2.50)
| | | | | | | | | | | | 2. Abstinent vs. other:
| | | | | | | | | | | | Physical health:; a) disability: 33.0% vs. 53.1%, p=**; b) hepatitis: 41.6% vs. 41.7%, p=NS; c) HIV: 0.9% vs. 1.6%, p=NS; d) STDs: 24.1% vs. 30.5%, p= NS
| | | | | | | | | | | | Mental health, mean, (sd):; e) depression: 1.32 (0.38) vs. 1.54 (0.58), p=**; f) anxiety: 1.19 (0.28) vs. 1.40 (0.48) p=**; g) 1.39 (0.34) vs. 1.56 (0.49) p=**; h) OCD: 1.51 (0.46) vs. 1.66 (0.59), p=*; i) interpersonal sensitivity: 1.32 (0.35) vs. 1.50 (0.48), p=**
Fridell 2006 ^36^ | Prospective cohort, some cross-sectional analyses | A | N | 125 at intake; | “Drug abusers” admitted to detoxification & rehabilitation inpatient unit in Lund, Sweden, in 1988-89 | NR | Mixed: amphetamines (39%), opiates (28%), cannabis (18%), tranquilizers (11%); | 1) Abstinence, ascertained at 5 yr fup, defined as no use of illegal drugs & no abuse of alcohol vs. other (42% abstinent for past 6 mos.); 2) Length of time abstinent at 5 yr fup | 10 yr (5yr fup to 15 yr fup); | Survival analysis (15 yr mortality); | Mortality (24% at 15 yr fup) | Coefficient for time abstinent at 5 yr fup: -0.30, Wald statistic = 1.88, p=NS (n=90) | 3 time points, strengthens (null) mortality findings; small sample, cross-sectional analysis of 5-yr data limits inferences
Good | | | | 90 at fup | | | | | (5 yr: intake to 5 yr fup) | Cross-sectional (5 yr fup) | GAF, GSI (at 5 yr fup only) | GAF reported only for 5 yr fup (cross-sectional, n=90):
| | | | | | | | | | | | Abstinent = 75
| | | | | | | | | | | | Other = 64, p=***
| | | | | | | | | | | | GSI at 5 yr fup:
| | | | | | | | | | | | Abstinent = 54
| | | | | | | | | | | | Other = 60, p=*
Lucas 2001 ^37^ | Prospective cohort, with cross-sectional analyses | A | N | 764 | Attendees at an HIV-1 specialty clinic in Baltimore, MD who consented, completed an interview, and met criteria for HAART | NR | Heroin or cocaine | Drug use categories, based on self-report: | Essentially 6 mos. (retrospective report of drug use history) | Multivariate logistic & linear regr | 1 Never vs. ever used HAART (full sample);; 2 Medication nonadherence (n=127) vs. adherence (n=431) among subsample taking HAART, (n=558);; 3 Virologic & immunologic responses to HAART, among subsample taking HAART, (n=558) | 1. Never vs. ever used HAART, Adj. OR (CI): | Limited by ascertainment of drug use status at only one time point, lack of adjustment for tobacco use or psychiatric conditions (e.g., depression)
Fair | | | | | | | | Never: never used drugs (n=189); | | | | Never (ref)
| | | | | | | | Former: past use of heroin or cocaine, but not in 6 mos. Before interview (n=376); | | | | Former = 1.6 (1.0–2.7)
| | | | | | | | Active: used heroin or cocaine in past 6 mos. (n= 199); | | | | Active = 4.8 (2.8–8.3)
| | | | | | | | | | | | 2. % medication nonadherence:
| | | | | | | | | | | | Never = 24%
| | | | | | | | | | | | Former = 17% (p=NS compared to Never)
| | | | | | | | | | | | Active = 34%
| | | | | | | | | | | | (p=0.05 compared to Never; p=*** compared to Former)
| | | | | | | | | | | | 3. Median reduction in HIV-1 RNA level: Never vs. Former (p=NS); Never vs. Active (p=***); Former vs. Active (p=***);
| | | | | | | | | | | | Median increase in CD4+ lymphocyte count: Never vs. Active (p=**); Former vs. Active (p=**)
Bouhnik 2004 ^38^ | Prospective cohort, with cross-sectional analyses | A | N | 144 | Among HIV-positive patients enrolled in a larger cohort study, those who self-reported as IDU's at enrollment, and reported cessation of IDU ≥12 mo or continued IDU at 18 mo. fup | Missed more than 1 visit between enrollment & 18 mo. fup (n=33); IDU cessation < 12 mo. at 18 mo. fup (n=20) | NR (injected drugs, likely heroin or cocaine) | IDUs (n=54) vs. Ex-IDUs (n=90) | Essentially 12-mos. (retrospective report of recent IDU) | Cross-sectional; univariate logistic regression | CES-D (depressive symptoms) >= 16; | CES-D: | 2 time points, with retrospective ascertainment of IDU cessation. Analyses unclear regarding adjustment for covariates.
Fair | | | | | | | | | | | Immunologic (CD4 cell count) & virologic (plasma viral load) indicators of HIV progression; | IDU= 40.7%
| | | | | | | | | | | HAART participation (y/n); | Ex-IDU= 20.0%, p=**; OR=0.36 (0.17–0.77)
| | | | | | | | | | | Inconsistent condom use (y/n) | CD4 cell count:
| | | | | | | | | | | | IDU=456
| | | | | | | | | | | | Ex-IDU=397, p=0.052, OR=0.85 (0.73–1.00);
| | | | | | | | | | | | Plasma viral load (log copies/ml):
| | | | | | | | | | | | IDU=3.40
| | | | | | | | | | | | Ex-IDU=3.24, p=ns, OR= 0.90 (0.64–1.27)
| | | | | | | | | | | | HAART participation:
| | | | | | | | | | | | IDU=66.7%
| | | | | | | | | | | | Ex-IDU=80.0%, p=ns, OR=2.00 (0.93–4.30)
| | | | | | | | | | | | Inconsistent condom use:
| | | | | | | | | | | | IDU=40.7%
| | | | | | | | | | | | Ex-IDU=20.0%, p=**, OR=0.36 (0.17–0.77)
Knowlton 2001 ^41^ | Prospective cohort, with cross-sectional analyses | Y, A | N | 503 at intake; | Subset from larger study (ALIVE), initial criteria age >= 18, injected drugs in past 10 yrs | NR | Heroin & cocaine | Former drug users (stopped b/n baseline & fup) compared to continuing users | 1 yr | Multiple logistic regr | High (>=16) vs. lower CES-D score | Adj. OR = 0.40** | 2 time points, correlational results; lack of adjustment for tobacco use limits interpretation of association between stopping drug use & depression
Fair | | | | 393 at fup | | | | | | | | (Beta=-0.92, SE=0.35)
| | | | | | | | | | | | (adjusted for baseline drug use, functional limitations, perceived social support, depressive symptoms; plus declining physical function measured at fup
Gossop 2000 ^42^ | Prospective cohort, with cross-sectional analyses | A | N | 667 at intake; | Problem drug users beginning a new methadone treatment episode during March-July 1995; able to provide address in the UK | Primary diagnosis of alcohol dependence, previous | Opioids (heroin, illicit methadone), benzodiazepines, cocaine, amphetamines | 4 groups, based on cluster analysis of drug use at baseline and fup: | 1 yr | Repeated measures ANCOVA | Physical health index; anxiety & depression index (not described in article) | Physical health, mean (sd) at intake & fup: | Useful groupings of longitudinal drug use patterns. 2 time points, correlational results. Some concern about adequacy of adjustment for baseline differences between analysis groups
Fair | | | | 478 at fup | | | | Group 1 (improved response #1, n=121, 25%): high frequency opiate users at baseline, greatly reduced opiate, stimulant, and benzodiazepine use at fup; | | | | Group 1:
| | | | | | | | Group 2 (improved response #2, n=162, 34%): | | | | 16.8 (7.8), 11.5 (6.9)
| | | | | | | | Mainly used opiates at baseline, decreased opiate use significantly, but slightly increased benzodiazepine use; | | | | Group 2:
| | | | | | | | Group 3 (poor response, n=88, 18%): | | | | 16.2 (8.3), 12.0 (8.2)
| | | | | | | | No change in opiate or stimulant use, slight increase in benzodiazepine use; | | | | Group 3:
| | | | | | | | Group 4 (low rate use, n=107, 22%): | | | | 18.2 (8.6), 17.6 (8.1)
| | | | | | | | Relatively low use of opiates, stimulants & benzodiazepines at baseline, reduction in benzodiazepines. | | | | Group 4:
| | | | | | | | | | | | 12.9 (7.1), 11.1 (7.9)
| | | | | | | | | | | | Group diff. F (3,470)= 10.46, p=***
| | | | | | | | | | | | Anxiety & depr, mean (sd) at intake & fup:
| | | | | | | | | | | | Group 1:
| | | | | | | | | | | | 3.0 (1.8), 2.6 (1.8)
| | | | | | | | | | | | Group 2:
| | | | | | | | | | | | 3.1 (1.8), 2.7 (2.1)
| | | | | | | | | | | | Group 3:
| | | | | | | | | | | | 3.2 (2.1), 3.7 (2.0)
| | | | | | | | | | | | Group 4:
| | | | | | | | | | | | 3.3 (1.9), 2.5 (2.0)
| | | | | | | | | | | | Group diff. F (3, 470)=8.99, P=***
Moatti 2000 ^40^ | Prospective cohort, with retrospective analyses | Y, A | N | 164 | HIV patients infected through injecting drug use. | NR | NR (injected drugs, likely heroin or cocaine) | Group 1. On buprenorphine drug maintenance treatment (n=32); | Essentially 6 mos. (retrospective report of recent drug use) | Univariate comparisons of medians (Mann-Whitney test), logistic regression | Short-term adherence to antiretroviral drug therapy, based on self-report to nurse examiner and self-administered questionnaire. | Adherent, n (%): | HIV clinic patients, small samples in analysis groups, limit generalizeability
Fair | | | | | Age 18+; CD4 cell counts >= 300 × 10^6^ / l in last visit before enrollment; no opportunistic infections | | | Group 2. Ex-IDU, stopped >= 6 mos. Ago (n=113) | | | “Non-adherence” defined as reporting less than 80% of total dose of antiretroviral drug, or reporting not being “totally adherent” with HAART, during prior week. | Group 1: 25 (78.1)
| | | | | | | | Group 3. Active IDU, not on Buprenorphine drug maintenance treatment (n=19) | | | | Group 2: 74 (65.5)
| | | | | | | | | | | | Group 3: 8 (42.1)
| | | | | | | | | | | | Adj OR (CI):
| | | | | | | | | | | | Group 1 (ref)
| | | | | | | | | | | | Group 2: 2.32 (0.83–6.48)
| | | | | | | | | | | | Group 3: 5.09 (1.29–20.13)
| | | | | | | | | | | | Adjusted for sex, age, education, employment, alcohol consumption, index of negative life events, social support, clinical stage, # HIV symptoms, # HAART prescribed pills, prior antiretroviral treatment, time since initiated HAART, specific protease inhibitors used
Lucas 2006 ^39^ | Prospective cohort | Y, A | N | 1851 persons; | Attendees at an HIV-1 specialty clinic in Baltimore, MD who consented, completed >=1 interview, and met criteria for HAART | NR | Heroin or cocaine | Based on reported drug use: | Up to 5 years | For primary outcome: | Primary: | Primary (OR, 95% CI): | Strong within-person analyses; HIV clinic patient sample limits generalizeability
Fair | | | | 5,486 surveys | | | | Group 1: nonusers (n=1028) | | Joint longitudinal-survival model with time-dependent variables | Development of new “opportunistic conditions” related to HIV disease progression; coded 1 if any present during a 6-mo. period | Group 1 (ref)
| | | | 65% of participants completed >1 survey | | | | Group 2: intermittent users, abstinent during past 6 mos. (time dependent); | | For secondary outcome: | Secondary: | Group 2 =
| | | | | | | | Group 3: intermittent users, active during past 6 mos. (time dependent; | | Cox survival analysis | mortality, over 3-yr period | 1.4 (1.0, 1.9)
| | | | | | | | n=588 for groups 2 + 3, NR separately); | | | | Group 3 =
| | | | | | | | Group 4: persistent users (n=235) | | | | 2.3 (1.5, 3.0)
| | | | | | | | | | | | Group 4 =
| | | | | | | | | | | | 2.1 (1.4, 3.1)
| | | | | | | | | | | | Adjusted for age, sex, race, peak HIV-1 RNA, nadir CD4 cell count, at-risk alcohol use
| | | | | | | | | | | | Secondary (hazard ratio, 95% CI):
| | | | | | | | | | | | Group 1 (ref)
| | | | | | | | | | | | Groups 2+3 =
| | | | | | | | | | | | 1.9 (1.4, 2.4)
| | | | | | | | | | | | Group 4 =
| | | | | | | | | | | | 2.9 (2.1, 4.1)
| | | | | | | | | | | | Adjusted for age, sex, race, peak HIV-1 RNA, nadir CD4 cell count
Shankaran 2004 ^43^ | Retrospective cohort | P | N | 651 | Age 18+; delivery in participating hospital; birth weight, 1500 g OR >=1500 g plus birth occurred during specified recruitment hours | Birth outside catchment area for fup; multiple gestation; maternal psychosis | Cocaine, cannabis | All who self-reported drug use during pregancy AND confirmed by baby's meconium; | NA; mothers interviewed at 1-mo. well-baby check | Multivariate linear regression; covariates included patterns of use of other substances, clinic, maternal race, maternal age, parity, prepregnancy weight, gestational age, infant gender, socioeconomic status | Birthweight, length at birth, head circumference at birth | Among 15 comparisons for each drug (5 groups × 3 outcomes): | 90/745 (12.1%) with meconium positive for cocaine or opiates denied use and were dropped from analysis. Likely bias as a result.
Fair | | | | | | | | Divided into 5 groups, for each drug: | | | | Cocaine: | 2 significant associations with cocaine use not consistent with dose-response relationship
| | | | | | | | consistently high use, consistently moderate use, consistently low use, increasing use, decreasing use (change in use based on use in 3-mos before pregnancy & first trimester with use during trimesters 2 & 3) | | | | All NS except 2:
| | | | | | | | Group-matched with comparison group not exposed to cocaine or opiates | | | | low users' birthweight < non-users';
| | | | | | | | | | | | moderate users' head circumf. < non-users'
| | | | | | | | | | | | Cannabis: All NS
Chasnoff 1989 ^44^ | Retrospective cohort | P | N | 115 (94, 89 for some analyses) | Cocaine-exposed groups attended clinic that provided substance abuse and perinatal care, 1986-early 1988, used cocaine during pregnancy; comparison group with no drug use history received perinatal care at same hospital. | Opiate use during pregnancy; | Cocaine | Group 1: used cocaine during first trimester only (n=23); | NA; through childbirth | Chi-square, ANOVA | Perinatal complications; neonatal growth parameters (full-term infants only, among 94 mothers); Neonatal Behavioral Assessment Scale (7 dimensions) | Complications, %: | Small, highly selected samples limit inferences & generalizeability.
Fair | | | | | | 34 whose temporal patterns of cocaine use during pregnancy differed from those of 2 cocaine-exposed study groups | | Group 2: used cocaine throughout pregnancy (n=52); | | | | preterm delivery: | Few direct comparisons between cocaine-exposed groups; group-matching may not adequately adjust for baseline differences between groups
| | | | | | | | Group 3: did not use any drugs or alcohol throughout pregnancy (n=40) | | | | Group 1, 17%
| | | | | | | | | | | | Group 2, 31%
| | | | | | | | | | | | Group 3, 3% (p=**)
| | | | | | | | | | | | low birth weight:
| | | | | | | | | | | | Group 1, 0%
| | | | | | | | | | | | Group 2, 25%
| | | | | | | | | | | | Group 3, 5% (p=**)
| | | | | | | | | | | | small for gestational age:
| | | | | | | | | | | | Group 1, 0%
| | | | | | | | | | | | Group 2, 19%
| | | | | | | | | | | | Group 3, 3% (p=*)
| | | | | | | | | | | | abruptio placentae:
| | | | | | | | | | | | Group 1, 9%
| | | | | | | | | | | | Group 2, 15%
| | | | | | | | | | | | Group 3, 0% (p=*)
| | | | | | | | | | | | Neonatal growth, mean (sd):
| | | | | | | | | | | | Weight, g:
| | | | | | | | | | | | Group 1,
| | | | | | | | | | | | 3160 (453)
| | | | | | | | | | | | Group 2,
| | | | | | | | | | | | 2829 (708)
| | | | | | | | | | | | Group 3,
| | | | | | | | | | | | 3436 (628). Group 1 vs. Group 3, p=NS.
| | | | | | | | | | | | Group 2 vs. Group 3, p=**
| | | | | | | | | | | | Length, cm:
| | | | | | | | | | | | Group 1,
| | | | | | | | | | | | 49.3 (2.5)
| | | | | | | | | | | | Group 2,
| | | | | | | | | | | | 48.0 (3.6)
| | | | | | | | | | | | Group 3,
| | | | | | | | | | | | 51.1 (2.9). Group 1 vs. Group 3, p=NS.
| | | | | | | | | | | | Group 2 vs. Group 3, p=**
| | | | | | | | | | | | Head circum., cm:
| | | | | | | | | | | | Group 1,
| | | | | | | | | | | | 33.4 (2.2)
| | | | | | | | | | | | Group 2,
| | | | | | | | | | | | 32.7 (2.3)
| | | | | | | | | | | | Group 3,
| | | | | | | | | | | | 34.6 (1.6). Group 1 vs. Group 3, p=NS.
| | | | | | | | | | | | Group 2 vs. Group 3, p=**
| | | | | | | | | | | | Neonatal Behavioral Assessment Scale:
| | | | | | | | | | | | Groups 1 & 2 had worse scores than Group 3 on 4 of 7 dimensions (p=*)

* p<0.05,

** p<0.01,

*** p<0.001

† Results at longest follow-up assessment

ANCOVA= Analysis of covariance; A =Adults (26+); CI=95% confidence interval; Fup= Follow-up; GAF=Global Assessment of Functioning; GSI=Global Severity Index; HAART=Highly active antiretroviral therapy; IDU=Injection drug use(r); MMT=Methadone maintenance treatment NA=Not applicable; NR=Not reported; NS=Not significant (p>0.05); OR=Odds ratio; P=Pregnant females; Sd=standard deviation; STD=sexually transmitted disease; T=Teen/Adolescents (12–17); Y=Young adults (18–25)

Among young-adult and adult populations, the strongest evidence for health benefits comes from evaluations of the association between stopping opiate (usually heroin) misuse and mortality. In a 15-year follow-up study of 188 persons treated for opiate dependence in a Danish community, Sorensen et al. ^35^ interviewed the sample 5 years following treatment, identifying groups that had either quit using opiates entirely, still used occasionally, or continued to use daily. The risk of mortality (hazard rate) over the succeeding 10 years (post-interview) was about half as high in the group who had quit, compared to the group who continued daily use [hazard ratio (95% CI): 0.45 (0.2, 0.8)]. These results were adjusted for age, gender, and number of mental health hospitalizations. Mortality progressively increased between those who had become abstinent at 5-year follow-up, those who occasionally used illegal drugs, and those who used illegal drugs daily. Compared to the general Danish population, mortality remained significantly elevated, however, even in the group that had become abstinent [Standard Mortality Ratio (95% CI): 7 (2.4, 17.0) among women, 8 (6.7, 21.6) among men]. The mortality evidence from Sorensen et al. may be considered stronger or more applicable to Key Question 7 than that from most other included studies because the longitudinal data covered three observation points—during treatment, 5 years post-treatment, and 15-years post-treatment—allowing clear temporal ordering between reported reduction of drug misuse and mortality over the succeeding 10 years. Two other studies in adults also observed samples over at least three time points. ^12,^ ^36^ Hser et al. ^12^ conducted a 33-year follow-up of 581 male, criminal offender heroin addicts receiving mandatory treatment in a California criminal justice setting in the period 1962 to 1964. Interviews were conducted in 1974-75, 1985-86, and 1996-97. Mortality was ascertained as of the latter two periods, at approximately 22 and 33 years after intake. There was no significant improvement in mortality in current non-users of heroin, compared with current users, at either the 22- or 33-year follow-ups. Cross-sectional analyses at the 1996-97 interview showed that non-users had significantly less disability, depression, and anxiety symptoms than current users, but there was no difference between these groups in proportions with hepatitis, HIV, or STDs. Although the sample of male heroin addicts in the Hser et al. study ^12^ was selected from a criminal justice-related population, reducing its generalizeability to primary care populations, the study was included here because of the value of its unusually long follow-up period. Fridell and Hesse ^36^ identified 125 “drug abusers,” two-thirds of whom reported injection drug use, who sought inpatient treatment in Sweden in 1988-89. Among ninety persons interviewed at 5 years post treatment, mortality was ascertained over the next 10 years. Survival analyses showed no significant association between length of time abstinent at 5-year follow-up and mortality. Cross-sectional analyses at the 5-year follow-up revealed higher global functioning and lower global psychiatric severity in persons who had been abstinent for 6 or more months compared with all others. In summary, across the three studies that examined mortality outcomes, only Sorensen ^35^ showed a reliable longitudinal association between cessation of opiate use and reduced mortality. Cross-sectional results were mixed, with some evidence of better functioning among drug misusers who were abstinent at the time of assessment, compared with continuing drug users.

Four studies ^37^ – ^40^ examined changes in drug misuse or injection practices in relation to adherence to needed medical treatment, to disease progression, or to mortality, among individuals in treatment for HIV. Lucas et al. ^37^ identified groups of former heroin or cocaine users (no use in past 6 months), never users, and current users among 764 persons who met criteria for HAART. In general, current users were significantly more likely than never users to have never used HAART. Among those taking HAART, current users were less likely to adhere to the medication regimen and had poorer responses to HAART. Former users were more similar to never users than to current users. In a later report from the same study site, Lucas et al. ^39^ compared the development of new opportunistic conditions among 1851 HIV patients using HAART across groups of non-drug users, intermittent drug users during abstinent periods, intermittent drug users during active use periods, and persistent drug users. During abstinent periods, intermittent users were not significantly more likely to develop new conditions compared to nonusers, but during active drug use periods, intermittent users had significantly higher risk of developing new conditions (about double that of nonusers). Mortality among intermittent users was intermediate between that of nonusers and persistent users.

Bouhnik et al. ^38^ followed 144 drug-injecting HIV patients over 18 months, finding that those who had quit injecting drugs for at least 12 months were significantly less likely to be depressed (symptom score) than those who continued to inject, although HAART participation and responses to treatment did not consistently differ. Moatti et al. ^40^ examined short-term HAART adherence among 164 HIV-positive injecting drug users, finding that adherence among individuals who had quit injecting drugs for the past 6 months or more was not significantly different from adherence among patients on buprenorphine maintenance treatment; in contrast, adherence among active injecting drug users was significantly lower than among patients in treatment. In a sample of 393 individuals who had injected drugs in the past 10 years, Knowlton et al. ^41^ found significantly lower odds of having depressive symptoms at 1-year follow-up among those who had stopped using all drugs versus those who continued to use. Gossop et al. ^42^ took a different approach in conducting cluster analyses of factors at intake among 478 persons beginning methadone treatment who participated in 1-year follow-up. Four clusters were identified based on drug use patterns both at intake and follow-up; the two clusters showing improved drug use patterns tended to have improved physical and mental health index scores at 1 year relative to the non-changing clusters. In summary, these six studies all found some associations between reduction or cessation of drug misuse and a variety of health outcomes. All but one of the studies ^39^ were limited by analyses of behavioral changes between only two time points, producing essentially cross-sectional results in which the timing of changes in drug use were contemporaneous with changes in health indicators.

Two studies assessing health outcomes associated with cocaine misuse were conducted among pregnant women. Shankaran et al. ^43^ examined patterns of cocaine and marijuana use (separately) during pregnancy in relation to weight, length, and head circumference of infants at birth. Patterns of drug use were identified by mothers' reports following live birth, based on reported drug use during two six-month time periods: the 3 months before pregnancy and the first trimester, and the second and third trimesters. Five patterns were examined across the two time periods: consistently high, consistently moderate, consistently low use, increasing use, and decreasing use. A group-matched comparison group of non-users of cocaine or opiates was identified. Results showed that no marijuana use pattern was related to any of the birth outcomes, compared to non-drug users. Consistently low cocaine use was associated with lower birth weight, and consistently moderate cocaine use was associated with smaller head circumference, compared to non-drug users, but no dose-response relationship was apparent, and decreasing cocaine use was not related to any of the three outcomes. In an earlier, smaller study (N=115), Chasnoff et al. ^44^ compared pregnancy complications and birth outcomes among women who were: a) exposed to cocaine in the first trimester only; b) exposed to cocaine throughout pregnancy; or c) not exposed to drugs or alcohol during pregnancy. Cocaine exposure throughout pregnancy was associated with more preterm deliveries, lower birth weights, being small for gestational age, and placental abruption than cocaine exposure limited to the first trimester exposure or no exposure. Neonatal weight and length were significantly lower among those who used cocaine throughout pregnancy compared to non-users, but were not significantly different for first trimester-only users. Both cocaine-exposed groups tended to have worse scores on a neonatal behavioral assessment scale than the non-exposed infants. In summary, evidence from these studies is limited to two small studies and mixed with regard to benefits of reducing or quitting drug use during pregnancy, with Shankaran et al. ^43^ finding little association between drug use patterns and birth outcomes, and Chasnoff et al. ^44^ finding that stopping cocaine use after the first trimester is associated with improvement in some outcomes, but not others, compared to a continuously exposed group.