# Methods

## Literature search and strategy

This staged review is intended to update the previous USPSTF report on drug misuse, which was based on an authoritative, but non-systematic, research review.^1^ Consequently, we conducted literature searches to systematically locate relevant literature for our critical key questions as follows (see Appendix A - Search Strategies).

For key question 1, we searched Ovid MEDLINE for the time period 1994–April 2006. Randomized controlled trials (RCTs), controlled clinical trials, and longitudinal cohort studies were included. We identified no relevant articles for this key question.

For key questions 4, 5, and 5a, we conducted a two-stage literature search to locate high-quality, relevant systematic reviews, supplemented by bridge searches as necessary. We also retrieved all potentially relevant treatment research or trials cited in the previous 1996 USPSTF report. Relevant systematic reviews were identified from four distinct searches of Ovid MEDLINE, the Cochrane Database of Systematic Reviews (CDSR), the Database of Abstracts of Reviews of Effectiveness (DARE), and PsycINFO for the time frame 1994–January 2006. We identified 14 high-quality systematic reviews that addressed treatment for one or more of the illicit drugs addressed in this report (heroin, cocaine, marijuana, multiple drugs). We used those systematic reviews as sources of relevant trials for this review, supplemented by a two additional searches for randomized or controlled clinical trials in Ovid MEDLINE and PsycINFO from 2001–April 2006. Additional articles were obtained from comparing reference lists of related reviews, studies, editorials, reports, websites, and by consulting experts. We identified 17 relevant articles for these key questions.

For key question 7, we searched Ovid MEDLINE for the time period 1994–April 2006. Randomized controlled trials (RCTs), controlled clinical trials, and longitudinal, cohort studies were included. We also retrieved all potentially relevant articles cited in the 1996 USPSTF report. We identified eleven relevant articles for this key question.

All studies were managed in an electronic database (Reference Manager^®^).

## Inclusion and exclusion criteria

Two investigators reviewed identified abstracts for potential relevance to all critical key questions and determined eligibility by applying inclusion and exclusion criteria specific to each critical key question (Appendix B - Inclusion and Exclusion Criteria). Full-text articles for included abstracts, articles from the previous USPSTF report, and articles located from existing systematic reviews were examined for relevance. Eligible studies provided data relevant to the critical key questions for marijuana, cocaine, opiates, or multiple substances, and were English-language, primary care feasible or referable (defined in Appendix B), conducted in a US (or applicable country), and examined adolescents/teens ages 12–17, young adults ages 18–25, adults ages 26+, or pregnant women. Studies of detoxification/withdrawal, comparative treatment effectiveness, and animal studies were not included.

For KQ 1, randomized controlled trials (RCTs), controlled clinical trials, and longitudinal cohort studies were included. For KQs 4, 5, and 5a, RCTs and controlled clinical trials were included. For KQ7, we included RCTs, controlled clinical trials, and longitudinal cohort studies.

## Data abstraction and critical appraisal

Data were extracted from each paper, entered into evidence tables, and for key questions 4, 5, and 5a, the main findings were highlighted in a summary table, with trials categorized by population, drug, and treatment type. Information abstracted in an evidence table for trials of drug treatment included: target population, whether the population was screened/not screened in primary care, total number of patients, patient inclusion/exclusion criteria, type of drug(s) treated, treatment and control conditions, treatment duration and longest follow-up, results (by key question), whether results differed at short follow-up(s), and reviewer comment. For key question 7, the following information was abstracted: study design, target population, whether the population was screened or not screened in primary care, total number of patients, inclusion criteria and sample description, exclusion criteria, type of drug(s), groups analyzed, length of follow-up(s), type of data analysis, outcome(s), results, and reviewer comment. A second investigator reviewed or abstracted studies if the initial investigator required confirmation of exclusion or inclusion criteria or data abstraction elements.

The quality of studies, including systematic reviews, was rated using design-specific criteria developed by the USPSTF (Appendix C)^14^ and others (Appendix D)^15,^ ^16^(Appendix E).^17^ Each study's overall rating is a combination of internal and external validity ratings. Throughout the literature review and data abstraction process, when reviewers disagreed, a final rating was reached through consensus.

## Size of literature reviewed

A total of 4587 unique citations were identified, 4459 by the literature searches and 128 from reference lists, suggested by experts, etc. (Appendix F - Search and Selection of the Literature). Six hundred and twenty seven abstracts were dual-reviewed (independently reviewed by two investigators) for papers showing direct evidence of screening related to reduced morbidity and/or mortality. None of these met the inclusion criteria (KQ 1). Three thousand four hundred and fifty nine abstracts were dual-reviewed for randomized controlled trials, controlled trials, systematic reviews or meta-analysis reports showing evidence that treatment improves morbidity and mortality, results in decreased drug misuse, or improves social and legal outcomes. Of these, 17 met the inclusion criteria (KQs 4, 5, 5a). One thousand eight hundred and fifteen abstracts were dual-reviewed from a search addressing whether decreased use or abstinence following drug misuse is reliably associated with reduced morbidity and mortality. Of these, 11 met the inclusion criteria (KQ 7).

Appendix F. Search and Selection of the Literature

## Literature synthesis

Since this staged review's primary purpose was to determine evidence sufficiency, we did not undertake quantitative data synthesis such as meta-analysis. These techniques are used to provide summary effect sizes or explore heterogeneity in systematic reviews of treatment. Instead, we qualitatively summarized our findings, with an emphasis on the best available evidence for each critical key question and the overall coherence of the evidence. This level of synthesis was appropriate to the decision being made by the USPSTF using this review.

## External review process

The USPSTF appointed liaisons to advise the Oregon Evidence-based Practice Center in formulating and reporting this focused systematic review. An additional set of outside experts provided advice in the review formulation stage and commented on a draft version of the evidence synthesis.