# Introduction

This report is a staged systematic review to update the 1996 U.S. Preventive Services Task Force (USPSTF) recommendation on screening for drug misuse.^1^ The USPSTF previously concluded there was insufficient evidence to recommend for or against routine screening for drug misuse in primary care. This report examines whether the evidence for the critical key questions is now sufficient for the USPSTF to make a recommendation on this topic.

## Background

### Prevalence and burden of disease

Illicit drug use and abuse are serious problems among adolescents, adults, and pregnant women in the United States. Substance Abuse and Mental Health Services Administration (SAMHSA) recently reported epidemiological data on drug use in its 2004 National Survey on Drug Use and Health (NSDUH).^2^ Among persons age 12 and older in 2004, 7.9% (19.1 million) reported using illicit drugs during the past 30 days, which is essentially unchanged since 2002. However, among adolescents age 12–17 rates of illicit drug use declined slightly from 11.6% in 2002, to 10.6% in 2004. Marijuana remains the most commonly used illicit drug in the US, with 14.6 million past-month users (6.1% of those age 12 and older). Rates of use have remained stable over the past decade.^3^ Among the 19.1 million past-month illicit drug users in 2004, 56.8% used marijuana only, 19.7% used marijuana with some other drug, and less than one-quarter (23.6%) used one or more illicit drugs other than marijuana.^2^ While cocaine is the second most commonly used single drug, it is used by less than 1% of the population (0.8%). Although other illicit substances are similarly used by a small minority—hallucinogens (0.4%), inhalants (0.3%), heroin (0.1%)—the potential for abuse or dependence is quite high. Among past-year heroin users, 67.8% met criteria for drug abuse or dependence.^2^

Peak illicit drug use in the US occurs between the ages of 18 and 20 years, with 21.7% of people in this age range having used drugs within the last month. Percentages of the population who use drugs monthly decrease steadily with age, down to 0.6% for those aged 65 or older. Rates of illicit drug use vary significantly across racial/ethnic groups, with persons reporting more than one race having the highest rates (13.3%), followed by American Indians or Alaska Natives (12.3%), African Americans (8.7%), whites (8.1%), and Hispanics (7.2%). Men are more likely to engage in drug use than women (9.9% vs. 6.1%), but adolescent rates (age 12 to 17) of current illicit drug use are similar for boys and girls (10.6% for both).

In 2004, 4.6% of pregnant women aged 15 to 44 years reported using illicit drugs within the last month, compared to 10.2% of women in the same age range who were not pregnant.^2^ A number of studies have found poor pregnancy, neonatal, and childhood outcomes among women who used illicit drugs during pregnancy.^4^

No significant changes over the past few years are reported in estimates of the percentage of the US population with dependence on or abuse of illicit drugs (3.2%). Among individuals with dependence or abuse diagnoses for any illicit drug in 2004, 61.2% were dependent upon or abused marijuana. Among past-year illicit drug users, the proportion classified with illicit drug dependence or abuse varies by specific drug: 67.8% among heroin users, 27.8% of cocaine users, and 17.6% of marijuana users, with lower percentages for other substances, including alcohol.^2^

### Burden of preventable illness/natural history

Illicit drugs, tobacco, and alcohol are responsible for more deaths, illness, and disabilities than from any other preventable condition.^5^ The World Health Organization Report 2002^6^ includes illicit drug use among the 10 leading preventable risk factors for years of healthy life lost and disability in developed countries.

Adverse health effects of drug use vary greatly depending on the type of drug used. These effects can range from acute cardiovascular complications, such as those seen with cocaine use, to the more controversial respiratory or amotivational syndrome seen with marijuana.^7^ One study compared the prevalence of medical conditions among 747 substance abuse patients with 3,690 demographically-matched controls from the same health maintenance organization.^8^ Approximately one third of the medical conditions examined were more common among substance abuse patients than among the matched controls, and several of the conditions were among the most costly. Illicit drug use can adversely affect both mother and fetus in multiple ways, including decreasing the likelihood of seeking adequate prenatal care, and reducing gestational length and birth weight.^9^

The economic cost of drug abuse in the US was $67 billion in 1990.^5^ Most of the total costs of drug misuse are primarily related to costs of crime loss and incarceration. Deaths and illness account for only 17 percent of total costs, and medical costs are less than 5 percent. The costs associated with AIDS, however, represent almost 10 percent of the total and will likely continue to increase, given the role that drug misuse (e.g., needle sharing and unsafe sexual practices among IV drug users) plays in the AIDS epidemic.^5^

In addition to negative physical outcomes and economic costs, drug misuse also increases the risk for child abuse and family violence. Living with someone who abuses drugs during childhood is associated with negative long-term outcomes, including increased likelihood of illicit drug use.^10^ The justice system expends enormous resources working with individuals who have been arrested for illicit-drug possession, drug trafficking, and other crimes committed while under the influence of drugs. Workplaces also suffer from reduced productivity.

The age at which drug use was initiated predicts subsequent abuse and dependence, with higher rates observed among persons who initiate use at younger ages. This trend has been observed in all demographic groups.^2^

Drug misuse is often characterized as a chronic illness, with similar issues to other chronic conditions, such as treatment adherence, relapse,^11^ and potentially long-term treatment. The life course of narcotics misuse often includes light drug use, heavy drug use, abstinence, treatment engagement, methadone maintenance, incarceration, and death. Hser and colleagues conducted longitudinal research with male addicts over a 33-year period. At follow-up, 49% had died (most commonly from accidental poisoning or drug overdose), 23% were abstinent, 13% were active opiate users, and 6% were incarcerated (9% were not interviewed).^12^ Less is known about the natural history for drugs other than heroin.

### Condition definition

The term “drug abuse” is ambiguous, having a general meaning in the US that includes a large range of illicit substance use and associated problems, and a specific definition within the Diagnostic and Statistical Manual (DSM IV-TR).^13^ For this review, we use the phrase “drug misuse” when referring to the wider range of illicit substance use, and reserve “drug abuse” for the DSM-IV-TR diagnostic designation (defined below).

Within the DSM-IV-TR, specific drug use disorders are defined within two categories: substance abuse disorders and substance dependence disorders. Criteria for these two clinical diagnoses are defined in the DSM IV-TR as follows:

#### Substance abuse

A) A maladaptive pattern of substance use leading to clinically significant impairment or distress, as manifested by one (or more) of the following, occurring within a 12-month period:
  1 Recurrent substance use resulting in a failure to fulfill major role obligations at work, school, or home (e.g., repeated absences or poor work performance related to substance use; substance-related absences, suspensions, or expulsions from school; neglect of children or household)
  2 Recurrent substance use in situations in which it is physically hazardous (e.g., driving an automobile or operating a machine when impaired by substance use)
  3 Recurrent substance-related legal problems (e.g., arrests for substance-related disorderly conduct)
  4 Continued substance use despite having persistent or recurrent social or interpersonal problems caused or exacerbated by the effects of the substance (e.g., arguments with spouse about consequences of intoxication, physical fights)
B) The symptoms have never met the criteria for Substance Dependence for this class of substance.^13^

#### Substance dependence

A maladaptive pattern of substance use, leading to clinically significant impairment or distress, as manifested by three (or more) of the following, occurring any time in the same 12-month period:

1 Tolerance, as defined by either of the following: a need for markedly increased amounts of the substance to achieve intoxication or desired effect markedly diminished effect with continued use of the same amount of the substance
2 Withdrawal, as manifested by either of the following: the characteristic withdrawal syndrome for the substance the same (or a closely related) substance is taken to relieve or avoid withdrawal symptoms
3 The substance is often taken in larger amounts or over a longer period than was intended
4 There is a persistent desire or unsuccessful efforts to cut down or control substance use
5 A great deal of time is spent in activities necessary to obtain the substance (e.g., visiting multiple doctors or driving long distances), use the substance (e.g., chain-smoking), or recover from its effects
6 Important social, occupational, or recreational activities are given up or reduced because of substance use
7 The substance use is continued despite knowledge of having a persistent or recurrent physical or psychological problem that is likely to have been caused or exacerbated by the substance (e.g., current cocaine use despite recognition of cocaine-induced depression, or continued drinking despite recognition that an ulcer was made worse by alcohol consumption)^13^

In DSM-IV-TR, substance use includes alcohol, illicit drugs, nicotine, and caffeine. While the work presented here excludes alcohol, nicotine, and caffeine, there remains a wide range of substances included under the definition of drug misuse (see Table 1). This updated review focuses on the misuse of marijuana, cocaine, heroin, or multiple substances. These conditions were chosen based on overall prevalence of use and prevalence of problematic use as indicated by the proportion of users meeting diagnostic criteria for abuse or dependence.

Table 1 Categories of Drugs Used Illicitly*

Included in Review
Category | Examples
Marijuana | Hashish
Cocaine | Crack
Opioids | Heroin

Not included in Review
Category | Examples
Hallucinogens | LSD, PCP, peyote, mescaline, mushrooms, “Ecstasy” (MDMA)
Inhalants | Amyl nitrite, cleaning fluids, gasoline, paint, glue
Pain relievers^†^ | Oxycodone (OxyContin), propoxyphene (Darvon), hydrocodone (Vicodin)
Tranquilizers^†^ | Diazepam (Valium), alprazolam (Xanax)
Stimulants^†^ | Dextroamphetamine (Dexedrine), methylphenidate (Ritalin), methamphetamine
Sedatives^†^ | Methaqualone (Quaalude), pentobarbital sodium (Nembutal),

* Nine categories based on Substance Abuse and Mental Health Services Administration; 2004 National Survey on Drug Use and Health (NSDUH). Available online at: http://www.oas.samhsa.gov/NSDUH.htm#NSDUHinfo. Accessed January 8, 2008

† Prescription type, non-medical use (psychotherapeutics); over-the-counter medications are excluded.

### Previous USPSTF recommendations

In 1996, the USPSTF concluded there is insufficient evidence to recommend for or against routine screening for drug abuse with standardized questionnaires or biologic assays (C recommendation).^1^ The 1996 Task Force review addressed the following substances: illicit drugs (e.g., cocaine, heroin, phencyclidine, methaqualone, hallucinogen, marijuana), legal drugs not prescribed by a physician (e.g., amphetamines, benzodiazepines, barbiturates, and anabolic steroids), and inhalants (amyl and butyl nitrite, gasoline, nitrous oxide, glue, other solvents). The Task Force addressed three separate populations for drug misuse screening: adolescents, adults, and pregnant women.

## Staged systematic review

To update this topic, we utilized an analytic framework (Figure 1) with eight Key Questions (KQs):

Figure 1. Drug* Misuse Analytic Framework and Key Questions

*Drugs included are opiates, cocaine, marijuana, and mixed drugs

KQ 1. Is there direct evidence that screening for drug misuse reduces morbidity and/or mortality?

KQ 2. Do screening tests accurately detect drug misuse?

KQ 3. Does screening for drug misuse result in adverse effects?

KQ 4. Does treatment for drug misuse among individuals identified through screening improve morbidity and/or mortality?

KQ 5. Does treatment for drug misuse among individuals identified through screening result in decreased drug misuse?

KQ 5a. Does treatment for drug misuse reduce risk behaviors or improve social and legal outcomes?

KQ 6. Does treatment for drug misuse result in adverse effects?

KQ 7. Is decreased use or abstinence following drug misuse reliably associated with reduced morbidity and mortality?

For this report, we used a staged review approach that focused first on the evidence for the following five critical key questions oriented toward the health benefits of treatment and on an overarching question determining whether there is direct evidence of benefit from screening to identify patients for treatment.

## Critical key questions

KQ 1. Is there direct evidence that screening for drug misuse reduces morbidity and/or mortality?

KQ 4. Does treatment for drug misuse among individuals identified through screening improve morbidity and/or mortality?

KQ 5. Does treatment for drug misuse among individuals identified through screening result in decreased drug misuse?

KQ 5a.Does treatment for drug misuse reduce risk behaviors or improve social and legal outcomes?

KQ 7. Is decreased use or abstinence following drug misuse reliably associated with reduced morbidity and mortality?

In the logic of the staged review, if the evidence for these critical key questions is insufficient to establish the links between drug misuse identification through screening, treatment, and clinically-meaningful health benefits, further systematic review to include the other key questions in the analytic framework is unwarranted. Insufficiency of evidence for these critical key questions indicates that the overall body of evidence is insufficient for a USPSTF recommendation for drug misuse screening as a clinical preventive service in primary care. Indication of sufficient evidence for critical key questions 4, 5, 5a, and 7 indicates that a full systematic review of all key questions would be warranted.