# Acknowledgements

This report was funded by AHRQ for the U.S. Preventive Services Task Force (USPSTF), and the investigators acknowledge the contributions of David Lanier, MD, Medical Officer, AHRQ. Members of the USPSTF who served as leads for this project include Carol Loveland-Cherry, PhD, RN, Lucy Marion, PhD, RN, Virginia Moyer, MD, MPH, and Steven Teutsch, MD, MPH. Investigators thank the following expert reviewers of this report for commenting on draft versions: Michael Dennis, PhD, Dennis McCarty, PhD, Paul Roman, PhD, William Miller, PhD, and A. Thomas McClellan, PhD. Investigators also thank Daphne Plaut, MS, MLS, Taryn Cardenas, BS, and Kevin Lutz, MFA for their assistance in the preparation of this report.