# Appendixes

Appendix A. Search Strategies

Appendix B. Inclusion and Exclusion Criteria

Appendix C. Excluded Studies at the Full Text Level

Appendix D. Study Quality Criteria

Appendix E. Search and Selection of the Literature Tree

Appendix F. Expert Reviewers

Appendix G. Evidence Table. Descriptive Data on RCT Treatment Trials: 2000-2006