# Appendix G. Evidence Table. Descriptive Data on RCT Treatment Trials: 2000-2006

Evidence Table. Descriptive Data on RCT Treatment Trials: 2000-2006

Study & Year | Risk Level (Low, Average, High) | Setting/Country | Inclusion/Exclusion Criteria | Demographics | Number Completed/ Number Enrolled | Treatment and Regimen | Treatment Rounds, n | Diagnosis - Screening Method (Gram Stain, Amsel) | Timing of Screening/Treatment (Gestational Age in Weeks) | Spontaneous Preterm Delivery (PTD) < 37 weeks | PTD < 34 weeks | PTD < 32 weeks | PTD < 28 weeks | Low Birth Weight (LBW) (<2500g) or Very Low Birth Weight (<1500 g) | Preterm Premature Rupture of Membranes (PPROM) | Inter-Uterine Death (IUD) | Neonatal Death (NND) | Perinatal Death (PND) | Other Outcomes | Adverse Effects | USPSTF Quality Rating (Good, Fair, Poor) & Jadad Score (0–5)
Kekki, 2001 ^22^ | Low | Multi-prenatal clinics, Finland | Exclude multiple pregnancies or women with previous PTD | Mean age, 28.8 y; predominantly white | 375 | Route: vaginal | 1 | Gram stain (Spiegel) | 1 10–17 weeks gestation; 2 1 week post first screening (Tx); 3 30–36 weeks gestation | Tx: 9/187 | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Peripartum infections | Vulvovaginal itching | Fair/Good
| | | | | Tx: 187 | Dosage: 2% clindamycin cream | | | | Placebo: 7/188 | | | | | | | | | Tx: 21/187 | Tx: 6/187 | 4
| | | | | Placebo: 188 | Duration: 7 days | | | | | | | | | | | | | Placebo: 33/188 | Placebo: 6/188
Kurkinen-Raty, 2000 ^59^ | Low | Multi-center, Finland | Exclude multiple pregnancies or women with previous PTD | Mean age, 27.9 y; race, NR; previous PTD, 10%; manual labor, 33%; middle- or upper-level employee, 67% | 101/123 | Route: vaginal | 1 | Gram strain (Spiegel) | 1 12 weeks gestation; 2 one week after treatment; 3 30th week gestation | Tx: 7/51 | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Puerperal infectious morbidity seen more in cases of persistent BV | Not reported | Fair
| | | | | Tx: 62 | Dosage: 2% clindamycin cream | | | | Placebo: 3/50 | | | | | | | | | | | 3
| | | | | Placebo: 61 | Duration: 7 days
Odendaal, 2002 ^58^ | Low, High | South Africa, Tertiary Academic Hospital | Exclude multiple pregnancies and known cervical incompetence, include if antibiotic-free for ≥14 days | Mean age, 21.6 y; race, NR; average unmarried, 86.4% | Both L and H risk: 931/995 | Route: oral | 2 | Exam and/or Gram stain (Spiegel) | 1 15–26 weeks gestation; 2 4 weeks post first screening (Tx) | Low risk: primigravidae | Low risk: primigravidae | Not reported | Low risk: primigravidae | Mean weight in grams (standard deviation) | Not reported | Low risk primigravidae | Low risk primigravidae | Low risk primigravidae | Apgar score | Occurrence or absence of adverse effects not reported | Fair
| | | | | Low risk: primigravidae | Dosage: Metronidazole 400 mg | | | | BV + Tx: 12/66 | BV + Tx: 2/66 | | BV + Tx: 1/66 | Low risk: primigravidae | | BV + Tx: 0/66 | BV + Tx: 1/66 | BV + Tx: 1/66 | | | 3
| | | | | 459/464 | Duration: twice daily for 2 days | | | | BV + Placebo: 13/82 | BV + Placebo: 4/82 | | BV + Placebo: 2/82 | BV + Tx: 2475 (980) | | BV + Placebo: 2/82 | BV + Placebo: 0/82 | BV + Placebo: 2/82
| | | | | BV + Tx: 66/67 | Placebo (vitamin C 100 mg twice daily for 2 days) | | | | BV - : 64/311 | BV - : 21/311 | | BV - : 2/311 | BV + Placebo: 2759 (683) | | BV - : 5/311 | BV - : 2/311 | BV - : 7/311
| | | | | BV + Placebo: 82/83 | | | | | High risk: multigravidae | High risk: multigravidae | | High risk: multigravidae | BV - : 2752 (792) | | High risk multigravidae | High risk multigravidae | High risk multigravidae
| | | | | BV - : 311/314 | | | | | BV + Tx: 30/70 | BV + Tx: 17/70 | | BV + Tx: 7/70 | | | BV + Tx: 4/70 | BV + Tx: 3/70 | BV + Tx: 7/70
| | | | | High risk: multigravidae | | | | | BV + Placebo: 12/51 | BV + Placebo: 6/51 | | BV + Placebo: 1/51 | | | BV + Placebo: 1/51 | BV + Placebo: 0/51 | BV + Placebo: 1/51
| | | | | 472/491 | | | | | BV - : 102/351 | BV - : 42/351 | | BV - : 14/351 | | | BV - : 12/351 | BV - : 6/351 | BV - : 18/351
| | | | | BV + Tx: 70/74
| | | | | BV + Placebo: 51/53
| | | | | BV - : 351/364
Guaschino, 2003 ^62^ | Average | Outpatient OB clinics, multi-center, Italy | Exclude multiple pregnancies; include asymptomatic, antibiotic-free for ≥15 d | Mean age, 29.1 y; race, NR; education, 12.5 y (Tx), 10.8 y (control) | 100/112 | Route: intra-vaginal | 1 | Gram Stain / Hillier 1992 (Nugent) | 14–25 weeks gestation | Tx: 6 | Not reported | Not reported | Not reported | Tx: 3 | Tx: 7 | Not reported | Not reported | Not reported | No difference in mean gestational age. | 1 case of suspected fracture of clavicle, randomization assignment not specified. | Poor
| | | | | Tx: 49/55 | Dosage: 2% clindamycin cream | | | | Control: 9 | | | | Control: 7 | Control: 3 | | | | Respiratory distress syndrome: 2 Tx (4.1%), 3 controls (5.9%), p=ns. | | 2
| | | | | Control: 51/57 | Duration: 7 days
Kiss, 2004 ^21^ | Average | Non-hospital OB clinics in Vienna, Austria | Exclude multiple pregnancies; include asymptomatic, no vaginal bleeding | Mean age, 28.9 y; race, 98% white | 4155/4429 | Route: Vaginal | 2 | Gram stain (Nugent score 3+) | 15–20 weeks gestation | Tx: 5 | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | Not reported for BV subgroup | None of the women reported adverse effects during the treatment period | Good
| | | | | | Dosage: 2% clindymacin cream | | | | Control: 8 | | | | | | | | | | | 4
| | | | | | Duration: 6 days
| | | | | | 2nd round: oral clindamycin
Lamont, 2003 ^61^ | Average | Hospital-based antenatal care; 3 sites in UK | Include ages 16–40 y, Gram stain consistent with BV, asymptomatic, 13–20 wk of gestation. Exclusions: history of antibiotic-related colitis, inflammatory bowel disease, or frequent periodic diarrhea; multiple pregnancies; and pregnancy complications. | Mean age, 27 y; race, 70% white, 15% black; previous PTD, 7.3% | 368/409 | Route: vaginal | 2 | Gram stain (Nugent) | 1 13–20 weeks gestation; 2 20–24 days after baseline visit; 3 24–48 hours post delivery | Tx: 8/208 | Not reported | Not reported | Not reported | Tx: 15/193 | Not reported | Tx: 3/140 | No difference | Not reported | Gestational age at delivery was statistically significantly lower in the placebo group, however it did not have an effect on the pregnancy outcomes. | Occurrence or absence of adverse effects not reported | Good
| | | | | Tx: 178/208 | Dosage: 2% Clindamycin cream, 5 grams | | | | Placebo: 19/201 | | | | Control: 18/204 | | Control: 1/142 | | | | | 5
| | | | | Placebo: 190/201 | Duration: 3 days
Larrson, 2006 ^60^ | Average | Southeast Health Care Region of Sweden | Include ≥18 y, asymptomatic, no antibiotic use in early pregnancy, Swedish-speaking. Exclude multiple pregnancies and other pregnancy complications. | Mean age, 28.5 y; race, 98% white; previous PTD, 9.2% (Tx), 6% (control) | 9025 enrolled and screened, 819 found BV+ and randomized: | Route: intra-vaginal | 2 or 3 | Gram stain (Nugent score >=6) | 10–14 weeks gestation | Tx: 11 | Tx: 2 | Tx: 1 | NR | Tx: 2 | NR | NR | NR | NR | Cumulative days of NICU: | 3 women withdrew from treatment because of persistent itching | Good
| | | | | Tx: 408/408 | Dosage: clindamycin cream for 7 days, vs. no treatment | | | | Control: 10 | Control: 4 | Control: 2 | | Control: 8 | | | | | Tx: 70 | | 4
| | | | | Control: 411/411 | Duration: 7 days | | | | | | | | | | | | | Control: 223

Abbreviations: A, Average; H, High; L, Low; Tx, Treatment.