# Appendix F. Expert Reviewers

- Carol Bruce, MPH, RN
- Centers for Disease Control Division of Reproductive Health, US Department of Health and Human Services
- Atlanta, GA

- J. Christopher Carey, MD
- Department of Obstetrics and Gynecology, Maricopa Medical Center and St Joseph's Hospital,
- Phoenix, AZ

- Subash Duggirala, MD
- Centers for Medicare and Medicaid Services, US Department of Health and Human Services
- Silver Spring, MD

- Juliette Kendrick, MD
- Centers for Disease Control Division of Reproductive Health, US Department of Health and Human Services
- Atlanta, GA

- Herbert Kiss, MD
- Associate Professor, Department of Obstetrics and Gynaecology, University of Vienna Medical School
- Vienna, Austria

- Emilia H. Koumans, MD, MPH
- Division of Sexually Transmitted Disease Prevention, Centers for Disease Control and Prevention, US Department of Health and Human Services
- Atlanta, GA

- Iris Mabry, MD, MPH
- Agency for Healthcare Research and Quality, US Department of Health and Human Services
- Rockville, MD

- Samuel F. Posner, PhD
- Centers for Disease Control, US Department of Health and Human Services
- Atlanta, GA

- Barbara Wesley, MD, MPH
- Food and Drug Administration, US Department of Health and Human Services
- Silver Spring, MD