# Appendix B. Inclusion and Exclusion Criteria

Inclusion Criteria:

Evaluates screening and/or treatment adverse effects and pregnancy outcomes for women with bacterial vaginosis (BV) and:
[underlined: Study designs:] systematic reviews, randomized control trials, or comparative effectiveness studies
[underlined: Populations:] pregnant women at low, average or high risk for preterm delivery
[underlined: Publication years:] studies included in previous review, and new studies published from 1996 - 2006
[underlined: Health outcomes:] preterm delivery, premature rupture of membranes, low birth weight, spontaneous abortion, endometritis/neonatal sepsis
[underlined: Conducted in a U.S. applicable country]
[underlined: Primary care feasible or referable:] see end of appendix for definitions

Exclusion Criteria:

Does not evaluate screening and/or treatment adverse effects and pregnancy outcomes for women with BV
[underlined: Study designs:] Editorials, letters, non-systematic reviews, non-comparative studies, case control studies, case studies, protocol (no data), comment/opinion, etc.
[underlined: Populations:] non-pregnant women, symptomatic for BV, multiple gestation
Selective population not normally seen in primary care (e.g. patients recruited from ER or other specialty setting who are injured or on drugs and do not represent a general patient population)
Study not conducted in a country applicable to the U.S. population
Non-humans
Non-English language
[underlined: Health Outcomes:] Does not report designated outcomes
[underlined: Setting:] Intervention not done in primary care, primary care-feasible, or widely available for primary care referral
[underlined: Study quality:] Does not meet criteria for quality

Overall Criteria for Judging if an Intervention is Primary CareFeasible:

[underlined: Whom Targeted:] Somehow involve individual-level identification of being a patient/in need of intervention
[underlined: Who Delivered:] Usually involve primary care clinicians (physicians in family practice, internal medicine, ob-gyn, pediatricians, GP), other physicians, nurses, nurse practitioners, or physician's assistants, or related clinical staff (dietitians, health educators, others counselors) in some direct or indirect way—or, at least, the intervention would be seen as connected to the health care system by the participant.
[underlined: How Delivered:] To individuals or in small groups (15 or less). Do not involve only or primarily group-level interventions outside the primary care setting to achieve behavioral changes. Generally involve no more than 8 group sessions total and intervention time period is no longer than 12 months.
[underlined: Where Delivered:] Could be delivered anywhere (including via the web, interactive technologies, in the home) if linked to primary care as above.

Definition of Primary CareReferable:

In order for an intervention to be feasible for primary care referral, it would need to be conducted as part of a healthcare setting or else be widely available in the community at a national level (such as a car seat fitting station within a hospital).