# Appendix A. Search Strategies

Specific Searches Per Key Question:

Key Question 1 - Screening
Database: Ovid MEDLINE
1 exp VAGINOSIS, BACTERIAL/di; 2 vaginosis.mp.; 3 exp Pregnancy Complications, Infectious/di, ep; 4 2 and 3; 5 exp PREGNANCY COMPLICATIONS/ or exp PREGNANCY/; 6 1 and 5; 7 exp mass screening/ or screen$.mp.; 8 pregnan$.mp. [mp=title, original title, abstract, name of substance word, subject heading word]; 9 7 and 8; 10 2 and 9; 11 4 or 6 or 10; 12 limit 11 to yr=“2000 - 2006”; 13 limit 12 to humans; 14 limit 13 to english language; 15 limit 13 to abstracts; 16 14 or 15
Key Question 2 - Treatment
Database: Ovid MEDLINE
1 exp VAGINOSIS, BACTERIAL/dt, th [Drug Therapy, Therapy]; 2 vaginosis.mp.; 3 exp Pregnancy Complications, Infectious/dt, th, pc; 4 2 and 3; 5 exp fetal membranes, premature rupture/dt, th, pc or exp labor, premature/dt, th, pc; 6 2 and 5; 7 exp PREGNANCY COMPLICATIONS/ or exp PREGNANCY/; 8 1 and 7; 9 4 or 6 or 8; 10 limit 9 to yr=“2000 - 2006”; 11 limit 10 to humans; 12 limit 11 to english language; 13 limit 11 to abstracts; 14 12 or 13
Key Question 3 - Adverse Effects
Database: Ovid MEDLINE
1 exp pregnancy/ or exp pregnancy complications/ or exp Embryonic Structures/de; 2 ((adverse$ adj5 effect$) or harm or harmed or harms or harming or defect$ or malform$).mp. [mp=title, original title, abstract, name of substance word, subject heading word]; 3 clindamycin.mp. or exp Clindamycin; 4 metronidazole.mp. or exp Metronidazole; 5 (ae or to or po).fs.; 6 2 or 5; 7 3 or 4; 8 1 and 6 and 7; 9 vaginosis.mp.; 10 exp Anti-Bacterial Agents; 11 exp Bacterial Infections/dh, dt, th [Diet Therapy, Drug Therapy, Therapy]; 12 10 or 11; 13 9 and 12; 14 1 and 6 and 13; 15 8 or 14; 16 limit 15 to (humans and english language)

Overall Searches:

Database: EBM Reviews - Cochrane Central Register of Controlled Trials
1 vaginosis.mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]; 2 (pregnan$ or labor or prematur$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]; 3 1 and 2
Database: EBM Reviews - Cochrane Database of Systematic Reviews
1 vaginosis.mp. [mp=title, abstract, full text, keywords, caption text]; 2 (pregnan$ or labor or prematur$).mp. [mp=title, abstract, full text, keywords, caption text]; 3 1 and 2
Database: EBM Reviews - Database of Abstracts of Reviews of Effects
1 vaginosis.mp. [mp=title, full text, keywords]; 2 (pregnan$ or labor or prematur$).mp. [mp=title, full text, keywords]; 3 1 and 2
Database: Pre-Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations
1 vaginosis.mp.; 2 (prematur$ or preterm$ or (pre adj term) or low birth weight$ or lbw or (spontaneous$ adj abort$)).mp. [mp=title, original title, abstract, name of substance word]; 3 1 and 2; 4 pregnan$.mp. [mp=title, original title, abstract, name of substance word]; 5 1 and 4; 6 3 or 5; 7 limit 6 to humans [Limit not valid; records were retained]; 8 limit 7 to english language; 9 limit 7 to abstracts; 10 8 or 9; 11 limit 10 to yr=“2000 - 2006”