# Discussion

## Screening

No studies compared pregnancy outcomes for pregnant women asymptomatic for BV in a screened population verses a non-screened population. Two good quality, large population-based screening and treatment trials in Sweden and Austria provide some data on screening and treatment and are discussed in the treatment section.

## Treatment

### Low- and Average-risk Women

The three BV treatment studies of women at low risk for a preterm delivery <37 weeks were not available for the 2001 report. The meta-analysis conducted for this review found no benefit to treating low-risk women for BV in reducing preterm deliveries.

Two good population-based screening and treatment trials in Sweden and Austria did not find a benefit for preterm delivery <37 weeks, while the Swedish trial found a small benefit for low birth weight. The meta-analysis for the average-risk women are consistent with the prior review in finding no benefit to screening and treating BV in the general population.^1^

### High-risk Women

Studies of screening and treating women asymptomatic for BV at high risk for preterm delivery show conflicting results for treatment benefit. It should be noted, however, that the 3 studies that reported significant treatment benefits also had placebo groups (BV positive) with a percentage of preterm delivery at 37 weeks greater than 30 percent. In contrast, the two high-risk studies that showed either significant treatment harm or no treatment effect had a lower percentage placebo baseline risk for PTD <37 weeks, 24% and 22.5% respectively. More research is needed to better understand this observation, and to explore relevance to other adverse pregnancy outcomes including preterm deliveries less than 34 weeks.

## Summary of Benefits and Harms

As noted in the 2001 report, the finding of benefit in some high-risk studies suggests that there may be a subgroup of high-risk women who benefit from screening and treatment for BV in pregnancy. The draft balance sheet in Table 4 updates the work of 2001 and summarizes our estimates of the consequences of screening for BV in 1000 patients from the general high-risk population and 1000 from a more selected high-risk population incorporating the new high-risk data. The base case for the general high-risk population incorporates the mean and 95% CIs from the two high-risk studies with approximately 23 percent of their placebo, BV-positive women experiencing a PTD <37 weeks^29,^ ^58^ for the listed outcomes. The second scenario incorporates the pooled results of the other three high-risk studies,^65^–^67^ where the percentage of BV-positive women in their placebo group experiencing a PTD <37 weeks is >30 percent (Table 3). For this work, we also assumed that the screening test has a sensitivity of 95% and specificity of 95%, the prevalence of unsuspected BV is 25%, and that adherence to treatment is 80%.

Table 4 Summary of Evidence Regarding the Benefits of Screening 1000 High-risk* Pregnant Women for Bacterial Vaginosis

| General high risk group | “More selected” high risk group
Benefit and Relevant Factors | PTD baseline risk <30% | PTD baseline risk > 30%
Assumptions
Proportion of pregnant women who meet criteria for screening | 0.10 | 0.03
Prevalence of BV in population | 0.25 | 0.25
Relative risk of PTD in patients with BV | 1.60 | 1.60
Sensitivity of screening test | 0.95 | 0.95
Specificity of screening test | 0.95 | 0.95
Adherence to treatment | 0.80 | 0.80
Effect sizes in patients with BV (Prob in control group - Prob in treated group, and 95% CI) †
PTD<37 weeks | -0.125 (-0.239 to -0.010)^29,^ ^58^ | +0.229 (+0.118 to +0.339)^65^–^67^
PPROM | -0.036 (-0.114 to +0.042)^29^ | +0.237 (+0.115 to +0.360)^65,^ ^67^
PTD<34 weeks | -0.033 (-0.126 to +0.060)^29,^ ^58^ | +0.079 (-0.026 to +0.183)^65,^ ^67^
Effect sizes in patients without BV (Prob in control group - Prob in treated group)
PTD<37 weeks | 0.00 | 0.00
PPROM | 0.00 | 0.00
PTD<34 weeks | -0.02 | -0.06
Results
# of patients with unsuspected BV | 250 | 250
# correctly diagnosed to have BV | 238 | 238
# of patients with BV who complete therapy | 190 | 190
# with BV missed | 13 | 13
# correctly diagnosed to not have BV | 713 | 713
# incorrectly diagnosed to have BV | 38 | 38
# of patients without BV who complete therapy | 30 | 30
# WITH BV missed or don't complete therapy | 60 | 60
# WITHOUT BV who don't complete therapy | 720 | 720
Outcomes
Decrease or increase in PTD<37 weeks | -24 (-45 to -2) | +44 (+22 to +64)
Decrease or increase in PPROM | -7 (-22 to +8) | +45 (+22 to +68)
Decrease or increase in PTD<34 weeks | -7 (-25 to +11) | +13 (-7 to +33)

Negative sign ( - ) indicates a net increase in adverse outcomes (harm)

Positive sign ( + ) indicates a net decrease in adverse outcomes (benefit)

* The proportion of all patients who meet the criteria for “high risk” varies with practice setting, patient population, and the criteria used to define “high-risk”.

† We used effect size data from high-risk studies where available for specific outcomes.

In the general high-risk population, of 1000 women screened, 238 are correctly diagnosed to have BV, and 190 of these complete therapy. With screening and treatment there would be 24 additional preterm deliveries before 37 weeks (95% CI=2 to 45 additional cases), 7 additional cases of preterm premature rupture of membranes (95% CI=8 fewer to 22 additional cases), and 2 fewer preterm deliveries before 34 weeks (95% CI=17 fewer to 13 additional cases). These results are similar to the 2001 report, however, the confidence interval for the PTD <37 weeks outcome does not include zero (no effect), indicating a significant result.

In the more selected high-risk group, results remain consistent with the 2001 report. Screening and treatment results in 44 fewer preterm deliveries before 37 weeks (95% CI=22 to 64), 45 fewer cases of preterm premature rupture of membranes (95% CI=22 to 68), and 11 fewer cases (95% CI=29 fewer to 8 additional cases) of preterm delivery before 34 weeks per 1000 women screened.

Because we assumed a potential increase in preterm delivery before 34 weeks in BV-negative patients that received BV treatment (based on Hauth 1995^66^), the effect of screening on preterm delivery less than 34 weeks is moderately sensitive to changes in the accuracy of the screening test. In the more selected high-risk group, for example, screening and treatment result in an increase in preterm delivery before 34 weeks if the specificity of the screening test for BV is below 80% (not shown).

## Adverse Effects of Screening and Treatment

There are no studies that directly address the issue of adverse effects of screening.

The effects of treatment on women incorrectly diagnosed to have BV have been indirectly studied. The previous review describes two studies of BV-negative women who received treatment for BV compared with BV-negative women who were not given antibiotics and found an increased frequency of PTD <34 weeks in the BV-negative group in both studies. A new study found that among FFN-positive/BV-negative women, there was a non-significant increase in spontaneous PTD <37 weeks in the treatment versus placebo group.

Recent observational studies confirm findings from the 2001 report of no association between metronidazole and congenital abnormalities. In terms of medication tolerability, there were no statistically significant differences between oral and vaginal clindamycin treatment and control groups, and oral and vaginal metronidazole showed high compliance and tolerability.

## Overall Evidence

Table 5 provides a summary for the level of evidence found for the critical key questions for this review.

Table 5 Summary of the Evidence

Critical Key Question | Assessment of Quality: Linkage Level* | Reviewed Evidence/Comment
KQ 1. Does screening for bacterial vaginosis during pregnancy reduce adverse pregnancy outcomes? In women at low, average, or high-risk for preterm delivery? | Poor | No studies found.
KQ 2. Does treatment of bacterial vaginosis during pregnancy reduce adverse pregnancy outcomes?
A In women at low-risk for preterm delivery; B In women at average-risk for preterm Delivery; C In women at high-risk for preterm delivery | Good | 3 RCTs^22,^ ^58,^ ^59^; meta-analysis PTD <37 weeks, ARR -0.019, 95% CI -0.056 to 0.018: no treatment effect.^†^
| Good^‡^ | 8 RCTs^21,^ ^29,^ ^60^–^65^[4 from 2001 report]; meta-analysis PTD <37 weeks, ARR 0.006, 95% CI -0.009 to 0.022: no treatment effect.
| Fair | 5 RCTs^29,^ ^58,^ ^65^–^67^[4 from 2001 report]; no treatment effect; significant heterogeneity. 3 show significant treatment benefit, one shows significant treatment harm, and one shows no effect of treatment.
KQ 3. What adverse effects does screening for bacterial vaginosis have on pregnancy outcomes? | Fair | No studies directly address this question; potential harm (increased risk for PTD) for misdiagnosis (BV negative patients receiving treatment) [2 from previous report, Hauth^66^ & Carey^29^]; Andrews^69^ showed potential harm of misdiagnosis, but it did not reach statistical significance.
KQ 3. What adverse effects does the treatment of bacterial vaginosis have on pregnancy outcomes? | Fair | Observational studies; congenital abnormalities; no association with metronidazole (confirms 2001 report findings).
| | Retrospective cohort; cancer outcomes, mixed results.
| | RCT's; tolerability, no differences between oral and vaginal clindamycin treatment and control groups.
| | Systematic Review; oral and vaginal metronidazole showed high compliance and tolerability.

* In evaluating the quality of the body of evidence concerning the linkages in the analytic framework, the topic team considers 3 criteria for a good, fair, or poor rating:

1 Aggregate internal validity
2 Aggregate external validity
3 Coherence / consistency

Reference: Harris, R., Helfand, M., Woolf, SH, Lohr, KN, Mulrow, CD, Teutsch, SM, Atkins, D. (2001). Current methods of the U.S. Preventive Services Task Force: A review of the process. American Journal of Preventive Medicine, 20 (Suppl 3): 21–35.

† Negative sign (-) indicates treatment harm; Positive sign (+) indicates treatment benefit.

‡ One RCT categorized data as average-risk; however, it is more likely a low-risk population. See average-risk category.

## Future Research

Future studies are needed to prospectively evaluate the benefit of screening and treating asymptomatic BV in women at highest risk for adverse pregnancy outcomes (e.g., greater than a 3-fold increased risk for PTD). Also, there remains substantial controversy regarding specific drugs chosen for BV treatment. Studies reported a wide range of treatment regimens, route, dose, duration, and treatment timing. The three studies with the highest preterm birth rates all reported significant treatment benefits, having used oral therapy (metronidazole). Agreement on treatment course would speed the field in moving forward to identifying the appropriate group and therapy for benefit.

The sample size for future studies needs to be calculated with better knowledge of the characteristics of the proposed study population, including characteristics such as race, the prevalence of BV, the preterm delivery rate (<37 as wells as <34 or <32 weeks), and the proportion of women with a prior spontaneous PTD. Studies thus far are relatively under-powered to study significant benefits for adverse pregnancy outcomes other than PTD <37 weeks. Perhaps a large health system or multi-site university-based research clinic or network collaboration might create this opportunity.

A report reviewer also suggested that future research in this area needs to specify the estimated reduction in relative risk expected in the trial. These assumptions have in general not appeared in publications of results of randomized trials. Perhaps these assumptions should be published so that future studies can benefit.

The importance of accurate screening to avoid treating BV-negative women needs attention. No studies assess what methods clinicians actually use to diagnose BV in practice, and whether clinicians routinely implement all of Amsel's clinical criteria before making a treatment decision. If minimal clinical criteria (e.g., microscopy and whiff test only) are routinely being used to diagnose BV in primary care or obstetric clinics, pregnant and non-pregnant women without BV may be inappropriately treated. Is it possible that more BV-negative women are given treatment in general practice settings, as opposed to research settings, where strict clinical criteria or lab tests are required to make treatment decisions? Again, the extent to which diagnosis and treatment in the research field applies to the clinical setting still remains unclear.

In typical ‘real-world’ clinical settings, the Amsel and Gram stain techniques for screening asymptomatic women for BV are not practical. Many clinicians often rely on two of Amsel's four criteria for diagnosis of BV (discharge and clue cells). In addition, Gram stains are subject to quality control mechanisms that are part of routine laboratory quality control protocols, conditions that the typical clinician using a microscope for a wet mount would not be subject to. The study of false-positive wet mount readings and clinician judgment and treatment preferences linked to pregnancy outcomes would provide more information in this field.

## References

1 Guise JM, Mahon S, Aickin M, et al. Screening for Bacterial Vaginosis in Pregnancy. Systematic Evidence Review No. 1 (Contract 290-97-0017 to the Oregon Health Science University Evidence-based Practice Center, Portland, Oregon. AHRQ Publication No. 01-S001. Rockville, MD: Agency for Health Research and Quality; April 2001.
2 Guise JM, Mahon SM, Aickin M, et al. Screening for bacterial vaginosis in pregnancy. Am J Prev Med. 2001;20(3 Suppl):62-72. [pmid: 11306234].
3 U.S. Preventive Services Task Force. Screening for bacterial vaginosis in pregnancy: recommendations and rationale. Am J Prev Med. 2001;20(3 Suppl):59-61. [pmid: 11306233].
4 Yudin MH. Bacterial vaginosis in pregnancy: diagnosis, screening, and management. Clin Perinatol. 2005;32(3):617-627. [pmid: 16085023].
5 Amsel R, Totten P, Spiegel C, et al. Nonspecific vaginistis. Diagnostic criteria and mircobial and epidemiologic associations. Am J Med. 1983;74:14-22. [pmid: 6600371].
6 Gravett M, Nelson H, DeRouen T, et al. Independent associations of bacterial vaginosis and Chlamydia trachomatis infection with adverse pregnancy outcome. JAMA. 1986;256:1899-1903. [pmid: 3761496].
7 Gravett M, Hummel D, Eschenbach D, et al. Preterm labor associated with subclinical amniotic fluid infection and with bacterial vaginosis. Obstet Gynecol. 1986;67:229-237. [pmid: 3003634].
8 Hillier S, Martius J, Krohn MA, et al. A case-control study of choropamnionic infection and histologic chorioamnionitis in prematurity. N Engl J Med. 1988;319:972-978. [pmid: 3262199].
9 Goldenberg RL, Iams JD, Mercer BM, et al. The preterm prediction study: the value of new vs. standard risk factors in predicting early and all spontaneous preterm births. NICHD MFMU Network. Am J Public Health. 1998;88(2):233-238. [pmid: 9491013].
10 Hillier S, Nugent RP, Eschenbach D, et al. Association between bacterial vaginosis and preterm delivery of a low-birth-weight infant. The Vaginal Infections and Prematurity Study Group. N Engl J Med. 1995;333:1737-1742. [pmid: 7491137].
11 Meis P, Goldene, Mercer B, et al. The preterm prediction study: significance of vaginal infections. National Institute of Child Health and Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. 1995;173:1231-1235. [pmid: 7485327].
12 Carey JC, Yaffe S, Catz C. The vaginal infections and prematurity study: an overview. Clin Obstet Gynecol. 1993;36:809-820. [pmid: 8293583].
13 Kurki T, Sivonen A, Renkonen O, et al. Bacterial vaginosis in early pregnancy and pregnancy outcome. Obstet Gynecol. 1992;80:173-177. [pmid: 1635726].
14 Minkoff H, Grunebaum A, Schwarz R, et al. Risk factors for prematurity and premature rupture of membranes: a prospective study of the flora in pregnancy. Am J Obstet Gynecol. 1984;150:965-972. [pmid: 6391179].
15 Klebanoff MA, Hillier SL, Nugent RP, et al. Is bacterial vaginosis a stronger risk factor for preterm birth when it is diagnosed earlier in gestation?. Am J Obstet Gynecol. 2005;192(2):470-477. [pmid: 15695989].
16 Azargoon A, Darvishzadeh S. Association of bacterial vaginosis, trichomonas vaginalis, and vaginal acidity with outcome of pregnancy. SO - Arch Iran Med. 2006;9(3):213-7. Jul. [pmid: 16859053].
17 Hillier S, Krohn MA, Nugent RP, et al. Characteristics of the three vaginal flora patterns assessed by gram stain among pregnant women. Vaginal infections and prematurity study group. Am J Obstet Gynecol. 1992;166:938-944. [pmid: 1372474].
18 Pastore LM, Royce RA, Jackson TP, et al. Associations between bacterial vaginosis and fetal fibronectin at 24–29 weeks' gestation. Obstet Gynecol. 1999;93:117-123. [pmid: 9916968].
19 Goldenberg RL, Klebanoff M, Nugent RP, et al. Bacterial colonization of the vagina during pregnancy in four ethnic groups. Am J Obstet Gynecol. 1996;174:1618-1621. [pmid: 9065140].
20 French JI, McGregor JA, Parker R. Readily treatable reproductive tract infections and preterm birth among black women. SO - Am J Obstet Gynecol. discussion 1726–7. Jun. 2006;194(6):1717-26. [pmid: 16731091].
21 Kiss H, Petricevic L, Husslein P. Prospective randomised controlled trial of an infection screening programme to reduce the rate of preterm delivery. BMJ. 2004;329(7462).
22 Kekki M, Kurki T, Pelkonen J, et al. Vaginal clindamycin in preventing preterm birth and peripartal infections in asymptomatic women with bacterial vaginosis: a randomized, controlled trial. Obstet Gynecol. 2001;97(5 Pt 1):643-648. [pmid: 11339909].
23 Hay PE, Morgan D, Ison C, et al. A longitudinal study of bacterial vaginosis during pregnancy. Br J Obstet Gynaecol. 1994;101:1048-1053. [pmid: 7826957].
24 Klebanoff MA, Hauth JC, MacPherson CA, et al. Time course of the regression of asymptomatic bacterial vaginosis in pregnancy with and without treatment. Am J Obstet Gynecol. 2004;190(2):363-370. [pmid: 14981375].
25 Nugent RP, Krohn MA, Hillier S. Reliability of diagnosing bacterial vaginosis is improved by a standardized method of gram stain interpretation. J Clin Microbiol. 1991;29:297-301. [pmid: 1706728].
26 Speigel C, Amsel R, Holmes KK. Diagnosis of bacterial vaginosis by direct gram stain of vaginal fluid. J Clin Microbiol. 1983;18:170-177. [pmid: 6193137].
27 Honest H, Bachmann LM, Knox EM, et al. Accuracy of various tests for bacterial vaginosis in predicting preterm birth: a systematic review. BJOG. 2004;111(5):409-422. [pmid: 15104603].
28 Hauth JC, Macpherson C, Carey JC, et al. Early pregnancy threshold vaginal pH and Gram stain scores predictive of subsequent preterm birth in asymptomatic women. Am J Obstet Gynecol. 2003;188(3):831-835. [pmid: 12634666].
29 Carey JC, Klebanoff MA, Hauth JC, et al. Metronidazole to prevent preterm delivery in pregnant women with asymptomatic bacterial vaginosis. N Engl J Med. 2000;342(8):534-540. [pmid: 10684911].
30 Mastrobattista JM, Bishop KD, Newton ER. Wet smear compared with gram stain diagnosis of bacterial vaginosis in asymptomatic pregnant women. Obstet Gynecol. 2000;96(4):504-506. [pmid: 11004348].
31 Gratacos E, Figueras F, Barranco M, et al. Prevalence of bacterial vaginosis and correlation of clinical to Gram stain diagnostic criteria in low risk pregnant women. Eur J Epidemiol. 1999;15(10):913-916. [pmid: 10669125].
32 Centers for Disease Control and Prevention. Guidelines for Treatment of Sexually Transmitted Diseases. MMWR. 1998. 1998;47:1-111.
33 Brocklehurst P, Hannah M, McDonald H. The management of bacterial vaginosis in pregnancy. Cochrane Database Syst Rev. 1998.
34 McDonald H, Brocklehurst P, Parsons J. Antibiotics for treating bacterial vaginosis in pregnancy. Cochrane Database Syst Rev. Issue 2. Available at: http://www.cochrane.org/reviews/en/ab000262.html Accessed: May 25, 2006.
35 Okun N, Gronau KA, Hannah ME. Antibiotics for bacterial vaginosis or Trichomonas vaginalis in pregnancy: a systematic review. Obstet Gynecol. 2005;105(4):857-868. [pmid: 15802417].
36 Riggs MA, Klebanoff MA. Treatment of vaginal infections to prevent preterm birth: a meta-analysis. Clin Obstet Gynecol. 2004;47(4):796-807. [pmid: 15596934].
37 Koumans EH, Markowitz LE, Hogan V, et al. Indications for therapy and treatment recommendations for bacterial vaginosis in nonpregnant and pregnant women: a synthesis of data. Clin Infect Dis. 2002;35(Suppl 2):S152-172. [pmid: 12353202].
38 Leitich H, Brunbauer M, Bodner-Adler B, et al. Antibiotic treatment of bacterial vaginosis in pregnancy: a meta-analysis. Am J Obstet Gynecol. 2003;188(3):752-758. [pmid: 12634652].
39 Thinkhamrop J, Hofmeyr Gy, Adetoro O, et al. Prophylactic antibiotic administration in pregnancy to prevent infectious morbidity and mortality [Systematic Review]. Cochrane Database Syst Rev. 2005;4:4.
40 Tebes CC, Lynch C, Sinnott J. The effect of treating bacterial vaginosis on preterm labor. Infect Dis Obstet Gynecol. 2003;11(2):123-129. [pmid: 14627219].
41 Varma R, Gupta JK. Antibiotic treatment of bacterial vaginosis in pregnancy: multiple meta-analyses and dilemmas in interpretation. Eur J Obstet Gynecol Reprod Biol. 2006;124:10-14. [pmid: 16129546].
42 Centers for Disease Control and Prevention. Sexually transmitted diseases treatment guidelines 2002 - Diseases characterized by vaginal discharge. MMWR. 2002;51(RR-6):43.
43 American College of Obstetricians and Gynecologists. ACOG Practice Bulletin. Assessment of risk factors for preterm birth - Clinical management guidelines for obstetrician-gynecologists. No 31. Obstet Gynecol. 2001;98(4):709-716. [pmid: 11592272].
44 British Association for Sexual Health and HIV and the Clinical Effectiveness Group. Revised national guideline for the management of bacterial vaginosis. Available at: http://www.bashh.org/guidelines/draft/draft_bv_guidelines_2004.doc. Accessed: May 31, 2006.
45 National Institutes of Health. Vaginitis Due to Vaginal Infections. Available at: http://www.niaid.nih.gov/factsheets/vaginitis.htm. Accessed: May 31, 2006.
46 American Academy of Family Physicians. Recommendations for Clinical Preventive Services - Bacterial Vaginosis. Available at: http://www.aafp.org/online/en/home/clinical/exam/a-e.html. Accessed: May 31, 2006.
47 National Institute of Clinical Excellence. Antenatal care: Routine care for the healthy pregnant woman. 2003. Available at: http://www.nice.org.uk/guidance/CG6. Accessed: Nov 11, 2006.
48 CIA World Factbook. Available at: http://www.cia.gov/cia/publications/factbook/. Accessed: June 1, 2006.
49 Slavin RE. Best evidence synthesis: an intelligent alternative to meta-analysis. J Clin Epidemiol. 1995;48(1):9-18. [pmid: 7853053].
50 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force. A review of the process. Am J Prev Med. 2001;30(3S):21-35. [pmid: 11306229].
51 Jadad A, Moore R, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17:1-12. [pmid: 8721797].
52 Oxman AD, Guyatt GH. Validation of an index of the quality of review articles. J Clin Epidemiol. 1991;44(11):1271-1278. [pmid: 1834807].
53 Furlan AD, Clarke J, Esmail R, et al. A critical review of reviews on the treatment of chronic low back pain. Spine. 2001;26(7):E155-162. [pmid: 11295917].
54 Thompson SG, Sharp SJ. Explaining heterogeneity in meta-analysis: a comparison of methods. Stat Med. 1999;18:2693-2708. [pmid: 10521860].
55 Egger M, Davey G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-634. [pmid: 9310563].
56 Terrin N, Schmid C, Lau J. In an empirical evaluation of the funnel plot, researchers could not visually identify publication bias. J Clin Epidemiol. 2005;58:894-901. [pmid: 16085192].
57 Rembold C. Number needed to screen: development of a statistic for disease screening. BMJ. 1998;317:307-312. [pmid: 9685274].
58 Odendaal HJ, Popov I, Schoeman J, et al. Labour-is bacterial vaginosis involved?. S Afr Med J. 2002;92(3):231-234. [pmid: 12040953].
59 Kurkinen-Raty M, Vuopala S, Koskela M, et al. A randomised controlled trial of vaginal clindamycin for early pregnancy bacterial vaginosis. BJOG. 2000;107(11):1427-1432. [pmid: 11117774].
60 Larsson PG, Fahraeus L, Carlsson B, et al. Late miscarriage and preterm birth after treatment with clindamycin: a randomised consent design study according to Zelen. BJOG. 2006;113(6):629-637. [pmid: 16709205].
61 Lamont R, Duncan S, Mandal D, et al. Intravaginal clindamycin to reduce preterm birth in women with abnormal genital tract flora. Obstet Gynecol. 2003;101(3):516-522. [pmid: 12636956].
62 Guaschino S, Ricci E, Franchi M, et al. Treatment of asymptomatic bacterial vaginosis to prevent pre-term delivery: a randomised trial. Eur J Obstet Gynecol Reprod Biol. 2003;110(2):149-152. [pmid: 12969574].
63 McGregor JA, French JI, Jones W, et al. Bacterial vaginosis is associated with prematurity and vaginal fluid mucinase and sialidase: results of a controlled trial of topical clindamycin cream. Am J Obstet Gynecol. 1994;170(4):1048-1059. [pmid: 8166188].
64 Joesoef MR, Hillier SL, Wiknjosastro G, et al. Intravaginal clindamycin treatment for bacterial vaginosis: effects on preterm delivery and low birth weight. Am J Obstet Gynecol. 1995;173(5):1527-1531. [pmid: 7503196].
65 McDonald HM, O'Loughlin JA, Vigneswaran R, et al. Impact of metronidazole therapy on preterm birth in women with bacterial vaginosis flora (Gardnerella vaginalis): a randomised, placebo controlled trial. BJOG. 1997;104(12):1391-1397.
66 Hauth JC, Goldenberg RL, Andrews WW, et al. Reduced incidence of preterm delivery with metronidazole and erythromycin in women with bacterial vaginosis. N Engl J Med. 1995;333(26):1732-1736. [pmid: 7491136].
67 Morales WJ, Schorr S, Albritton J. Effect of metronidazole in patients with preterm birth in preceding pregnancy and bacterial vaginosis: a placebo-controlled, double-blind study. Am J Obstet Gynecol. 1994;171(2):345-347. [pmid: 8059811].
68 Vermeulen G, Bruinse HW. Prophylactic administration of clindamycin 2% vaginal cream to reduce the incidence of spontaneous birth in women with increased risk: a randomised placebo-controlled double-blind study. BJOG. 1999;106:652-657.
69 Andrews WW, Goldenberg RL. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. What we have learned from an antibiotic trial in fetal fibronectin positive women. Semin Perinatol. 2003;27(3):231-238. [pmid: 12889590].
70 Diav-Citrin O, Shechtman S, Gotteiner T, et al. Pregnancy outcome after gestational exposure to metronidazole: a prospective controlled cohort study. Teratology. 2001;63(5):186-192. [pmid: 11320529].
71 Sorensen HT, Larsen H, Jensen ES, et al. Safety of metronidazole during pregnancy: a cohort study of risk of congenital abnormalities, preterm delivery and low birth weight in 124 women. J Antimicrob Chemother. 1999;44(6):854-856. [pmid: 10590296].
72 Czeizel AE, Rockenbauer M, Czeizel AE, et al. A population based case-control teratologic study of oral metronidazole treatment during pregnancy. BJOG. 1998;105(3):322-327.
73 Thapa PB, Whitlock JA, Brockman Worrell KG, et al. Prenatal exposure to metronidazole and risk of childhood cancer: a retrospective cohort study of children younger than 5 years. Cancer. 1998;83(7):1461-1468. [pmid: 9762949].
74 Ugwumadu A, Manyonda I, Reid F, et al. Effect of early oral clindamycin on late miscarriage and preterm delivery in asymptomatic women with abnormal vaginal flora and bacterial vaginosis: a randomised controlled trial. Lancet. 2003;361(9362):983-988. [pmid: 12660054].
75 Yudin MH, Landers DV, Meyn L, et al. Clinical and cervical cytokine response to treatment with oral or vaginal metronidazole for bacterial vaginosis during pregnancy: a randomized trial. Obstet Gynecol. 2003;102(3):527-534. [pmid: 12962937].