# Results

## Key Question 1. Screening of Pregnant Women Asymptomatic for BV and Pregnancy Outcomes

We did not find any studies that compared pregnancy outcomes for women asymptomatic for BV in a screened population and a non-screened population.

## Key Question 2. Treatment of Pregnant Women Asymptomatic for BV and Pregnancy Outcomes

### a. Low-risk Women

The previous review did not identify any low risk groups. Three fair or good quality randomized controlled treatment trials ^22,^ ^58,^ ^59^ with data for low risk (without a history of PTD) pregnant women are included in this review (Appendix G - Evidence Table). Two trials ^22,^ ^59^ treated women with one round of vaginal clindamycin, while the third used two rounds of oral metronidazole. ^58^ Pooled estimate in the low-risk studies showed no effect of treatment for PTD <37 weeks (ARR -0.019, 95% CI -0.056 to 0.018) (Tables 1 and 2). We did not find significant heterogeneity in the low risk trials. Confidence intervals for the individual studies and pooled results all cross zero with the absolute risk reduction (ARR) negative (Figure 2).

Table 1 Descriptive Characteristics, Percentage of PTD <37 Weeks in BV-positive Women, and Effect Sizes of Included Studies

| | | | | | Absolute Risk Reduction (ARR) (95% CI)
Study (Jadad score) | N completed/randomized | Screening method (at weeks gestation) | Treatment route, drug, dosage | PTD<37wks in untreated BV+ women (%) | PTD<37wks in treated BV+ women (%) | PTD < 37 weeks | PTD < 34 weeks | PTD < 32 weeks | PPROM | LBW <2500g
Low-risk Women
Kekki, 2001 ^22^ (4) | 375/375 | Gram stain (10 to 17) | Vaginal clindamycin 7d | 3.7 | 4.8 | -0.011 (-0.052, 0.030) | — | — | — | —
Kurkinen-Raty, 2000 ^59^ (3) | 101/101 | Gram stain (12) | Vaginal clindamycin 7d | 6.0 | 13.7 | -0.077 (-0.192, 0.038) | — | — | — | —
Odendaal, 2002 ^58^ (3) | 148/150 | Gram stain + Amsel (15 to 26) | Oral metronidazole 400mg BID 2d | 15.9 | 18.2 | -0.023 (-0.145, 0.099) | 0.019 (-0.044, 0.081) | — | — | —
Average-risk Women
Carey, 2000 ^29^ (5) | 1919/1953 | Gram stain (16 to 24) | Oral Metronidazole 2g repeat @48hr | 9.4 | 9.1 | 0.003 (-0.026, 0.032) | — | 0.004 (-0.010, 0.018) | -0.014 (-0.031, 0.003) | 0.005 (-0.024, 0.034)
Guaschino, 2003 ^62^ (2) | 100/112 | Gram stain (14 to 25) | Vaginal Clindamycin 7d | 15.7 | 12.3 | 0.034 (-0.101, 0.170) | — | — | -0.084 (-0.201, 0.033) | 0.076 (-0.040, 0.192)
Joesoef, 1995 ^64^ (4) | 681/745 | Gram stain (14 to 26) | Vaginal clindamycin 7d | 13.5 | 15.0 | -0.015 (-0.067, 0.037) | — | -0.021 (-0.049, 0.007) | — | -0.021 (-0.062, 0.020)
Kiss, 2004 ^21^ (4) | 292/297 | Gram stain (15 to 20) | Vaginal Clindamycin 6d | 5.7 | 3.5 | 0.022 (-0.025, 0.070) | — | — | — | —
Lamont, 2003 ^61^ (4) | 368/409 | Gram stain (13 to 20) | Vaginal clindamycin 3d | 9.8 | 4.3 | 0.055* (0.003, 0.108) | — | — | — | -0.022 (-0.081, 0.036)
McDonald, 1997 ^65^ (4) | 480/495 | Gram stain (16 to 26) | Oral Metronidazole 400mg BID 2d | 6.3 | 4.6 | 0.0166 (-0.024, 0.0571) | — | — | 0.017 (-0.015, 0.049) | -0.003 (-0.039, 0.033)
McGregor, 1994 ^63^ (3) | 129/142 | Gram stain + Amsel (16 to 27) | Vaginal clindamycin 7d | 7.2 | 14.9 | -0.077 (-0.186, 0.032) | — | — | -0.006 (-0.080, 0.068) | -0.092 (-0.192, 0.008)
Larsson, 2006 ^60^ (4) | 819/819 | Gram stain ( >=6) | Vaginal clindamycin 7d | 2.4 | 2.7 | -0.003 (-0.024, 0.019) | — | 0.0024 (-0.006, 0.011) | — | 0.015 (-0.0004, 0.030)
High-risk Women
Carey, 2000 ^29^ (5)^†^ | 210/213 | Gram stain (16 to 23) | Oral Metronidazole 2g repeat @48hr | 22.5 | 30.0 | -0.075 (-0.211, 0.061) | 0.012 (-0.067, 0.091) | — | -0.036 (-0.114, 0.042) | -0.040 (-0.156, 0.076)
Hauth, 1995 ^66^ (4) | 177/177 | Amsel (<24) | Oral metronidazole 250mg TID 7d + erythromycin 333mg TID 14d | 57.1 | 38.8 | 0.183* (0.027, 0.339) | — | — | — | —
McDonald, 1997 ^65^ (4)^†^ | 34/34 | Gram stain (16 to 26) | Oral Metronidazole 400mg BID 2d | 35.3 | 5.9 | 0.294* (0.041, 0.547) | 0.118 (-0.095, 0.331) | — | 0.176 (-0.006, 0.358) | 0.235 (-0.039, 0.509)
Morales, 1994 ^67^ (4) | 80/94 | Amsel (13 to 20) | Oral Metronidazole 250mg TID 7d | 44.4 | 18.1 | 0.263* (0.065, 0.461) | 0.066 (-0.054, 0.186) | — | 0.288* (0.122, 0.454) | 0.197* (0.006, 0.388)
Odendaal, 2002 ^58^ (3)^‡^ | 121/127 | Gram stain + Amsel (15 to 26) | Oral Metronidazole 400mgBID 2d | 23.5 | 42.9 | -0.193* (-0.358, -0.029) | -0.125 (-0.259, 0.009) | — | — | —
Vermeulen, 1999 ^68^ (4) | 16/22 | Gram stain (<26) | Vaginal Clindamycin 7d | — | — | — | 0.000 (-0.241, 0.241) | — | — | —

* Significant at p < 0.05

† Carey 2000 and McDonald 1997 performed a subgroup analyses of high-risk women. These women are included in the total population of average-risk women in these respective studies.

‡ Odendaal 2002 included two distinct populations: low risk women (i.e. primigravidae) and high risk women (i.e. history of PTD or other risk factor).

— means not reported

Negative ( - ) sign indicates increase in adverse events (treatment harm)

Positive ( + ) sign indicates a decrease in adverse event (i.e. treatment benefit)

Table 2 Absolute Risk Reduction (ARR)* Pooled Results for BV Treatment - Randomized Trials by Risk Level**

| Absolute Risk Reduction (ARR) (95% Confidence Interval)
| PTD < 37 weeks | PTD < 34 weeks | PTD < 32 weeks | PPROM | LBW <2500g
Low-risk | -0.019 (-0.056, 0.018) | — | — | — | —
Average-risk | 0.006 (-0.009, 0.022) | — | 0.0010 (-0.008, 0.010) | -0.006 (-0.030, 0.018) | -0.000 (-0.018, 0.018)
High-risk | Not pooled | 0.006 (-0.067, 0.079) | — | Not pooled | Not pooled

* ARR: difference in probability (control - treatment)

Negative ( - ) sign indicates increase in adverse events (treatment harm)

Positive ( + ) sign indicates a decrease in adverse event (treatment benefit)

** See Table 1 for specific data by study and risk level. Low-risk study references: 22, 58, 59; average-risk study references: 21, 29, 60, 61, 62, 63, 64, 65; high-risk study references: 29, 58, 65, 66, 67, 68.

Abbreviations: LBW, Low birth weight; PPROM, Preterm premature rupture of membranes; PTD, Preterm delivery.

Figure 2. Study characteristics and absolute risk reduction of preterm delivery (PTD) <37 weeks

Data for pooling results were not available for other adverse pregnancy outcomes for the low-risk group.

### b. General Population or Average-risk Women

Two good quality population-based BV screening and treatment trials of asymptotic pregnant women ^21,^ ^60^ were published since the 2001 report. Both screened a large asymptomatic sample of pregnant women in a general practice population for vaginal syndromes, randomized women to either treatment or placebo, and provided outcome data on adverse pregnancy outcomes. Additionally, one good ^61^ and one poor quality ^62^ randomized controlled treatment trial of average-risk pregnant women asymptomatic for BV are included since the last review (Appendix G - Evidence Table).

Pre-term delivery. A good quality population-based infection screening program trial ^21^ included twenty-five non-hospital-based clinics in Vienna Austria. Four thousand four hundred twenty-nine pregnant women were screened for multiple vaginal abnormalities, including BV (using gram stain), Candida, and Trichomonas vaginalis syndromes. This population was considered to be at average risk for a preterm delivery, as it included low-, average-, and high-risk women. (Appendix G - Evidence Table). BV was diagnosed using Nugent's criteria. Two hundred ninety-seven women were randomized to either intervention or placebo. Treatment consisted of clindamycin 2% vaginal cream for 6 days, and those women with persistent or recurrent BV at second screen were treated with oral clindamycin 300mg twice daily for 7 days. Authors report that the treatment group had significantly fewer preterm births at 37 weeks when compared to placebo. Using outcome data by infection type from this publication, this result does not remain significant for the BV group (ARR 0.022, 95% CI -0.025 to 0.070). In a post hoc analysis, it appears that the Candidiasis infection group provides the main effect for treatment in this study.

In another recent good quality, large population-based screening program, 9,025 asymptomatic pregnant women were screened in non-hospital based clinics in Sweden for BV. ^60^ BV was diagnosed using Nugent's criteria and the 819 women positive for BV were randomized to either placebo or treatment with clindamycin 2% vaginal cream (7 days). Persistent BV at second screen was treated again with this regimen. No benefit of treatment was found for PTD <37 weeks (ARR -0.003, 95% CI -0.024 to 0.019). ^60^

Two additional average-risk BV treatment trials published since 2001 reported mixed results. Lamont's good quality study of 409 women in the United Kingdom given 2% clindamycin cream for 7 days compared to placebo showed a small benefit for preterm delivery <37 weeks in the treatment group (ARR 0.055, 95% CI 0.003 to 0.108). ^61^ A poor quality study of 112 Italian women given the same regimen and dosage, without a second round of treatment, showed no benefit for treatment for PTD <37 weeks (ARR 0.034, 95% CI -0.101 to 0.170). ^62^

An updated meta-analysis pooling the PTD <37 weeks outcome for both the new average-risk treatment trials ^21,^ ^60^ – ^62^ with those reviewed in 2001, ^29,^ ^63^ – ^65^ showed no treatment benefit for PTD <37 weeks (ARR 0.006, 95% CI, -0.009 to 0.022). We did not find significant heterogeneity in the average risk trials (Figure 2).

No new studies for the general population looked at the outcome of PTD <34 weeks.

For PTD <32 weeks, one new average risk trial reporting this outcome showed no significant result. ^60^ When combined with the two studies ^29,^ ^64^ from the previous report providing PTD <32 week data, no treatment effect was found (ARR 0.001, 95% CI, -0.008 to 0.010) (Figure 3). We did not find significant heterogeneity in the average risk trials.

Figure 3. Absolute risk reduction of preterm delivery (PTD) <34 weeks and PTD <32 weeks

Other adverse pregnancy outcomes. Newly reviewed trials reporting a low birth weight outcome ^60,^ ^61,^ ^62^ showed no treatment effects. When combined with the 2001 report's average-risk population studies for this outcome, ^29,^ ^63^ – ^65^ the pooled estimate for the seven trials also showed no effect of treatment (ARR -0.000, 95% CI, -0.018 to 0.018) (Figure 4). Significant heterogeneity was not found in these trials.

Figure 4. Absolute risk reduction of low birth weight (< 2500g) and preterm premature rupture of membranes (PPROM)

For the PPROM outcome, one new average-risk trial ^62^ reported no treatment effects. When combined with the previously reviewed studies for this outcome, ^29,^ ^63,^ ^65^ pooled result indicated no treatment effect (ARR -0.006, 95% CI-0.030 to 0.018) (Figure 4).

### c. High-risk Women

We found one recently published study of high-risk pregnant women, defined as a history of PTD in a prior pregnancy. This was a fair quality study of 127 women in hospital clinics in South Africa treated with oral metronidazole (400 mg BID 2 days) ^58^ (Appendix G - Evidence Table).

Pre-term delivery. The high risk women in the new study showed a significant adverse effect of treatment for PTD <37 weeks (ARR -0.193, 95%CI, -0.358 to -0.029) ^58^ (Figure 2).

Trial data for the PTD <37 weeks outcome from high-risk patients for both the newly reviewed trial ^58^ and those reviewed in 2001, ^29,^ ^65^ – ^67^ showed significant heterogeneity (Q=22.432, df=4, P <0.0001), and treatment effects were not consistent in directions therefore were not pooled. Three ^65^ – ^67^ of the five trials saw a significant treatment benefit, while one showed significant treatment harm, ^58^ and the other showed no benefit ^29^ (Figure 2).

Pooling the PTD <34 weeks high risk population outcome for the new trial, ^58^ plus the 2001 report studies ^29,^ ^58,^ ^65,^ ^67,^ ^68^ indicates no significant treatment effect (ARR 0.006, 95% CI -0.067 to 0.079).(Figure 3). There was no significant heterogeneity seen for this outcome (p=0.219).

Other adverse pregnancy outcomes. Data for low birth weight and PPROM were not available for the new high-risk study. ^58^

2001 high-risk trial data ^29,^ ^65,^ ^67^ for LBW and PPROM outcomes were not pooled as and treatment effects were not consistent in directions and significant heterogeneity among the trials was detected (Q=6.362, df=2, P = 0.042 and Q=14.399, df=2, P = 0.001, respectively) (Figure 4).

Detailed study data on high-risk studies. A detailed summary of high-risk study characteristics, including aspects of treatment, setting, race, and the study population, is provided in Table 3. Further review of these data may provide additional information and a better understanding of the heterogeneity in this data, in order to enhance clinicians' decisionmaking for treatment choices.

Table 3 Study Characteristics of Women at High Risk for PTD <37 Weeks

Study (Jadad score) | Target population or Subset | HR criteria / definition of analyzed subset | Setting | Race* | Mean age (y)* | Other | N completed/ randomized | Screening method (at weeks gestation) | Treatment drug, route | 2nd round of treatment | PTD<37 wks in untreated BV+ women (%) | PTD<37 wks in treated BV+ women (%)
Carey, 2000 ^29^ (5)^†^ | Subset | Hx PTD | Multi-center trial of several university centers, U.S. | White 14.8% | 23.0 | — | 210/213 | Gram stain (16 to 23) | Oral metronidazole 2g repeat @48hr | Yes | 22.5 | 30.0
| | | | Black 69.5%
| | | | Hispanic 15.7%
Hauth, 1995 ^66^ (4) | Target | Hx PTD (analyzed subset) or pre-pregnancy wt <50 kg | University of Alabama, US | Black 73.6% | 23.7 | — | 177/177 | Amsel (>20) | Oral metronidazole 250mg TID 7d + Oral erythromycin 333mg TID 14d | Yes | 57.0 | 38.8
McDonald, 1997 ^65^ (4)^†^ | Subset | Hx PTD | 4 perinatal centers in a large metro area in Australia | White 87.4% | 26.2 | — | 34/34 | Gram stain (16 to 26) | Oral metronidazole 400mg BID 2d | Yes | 35.3 | 5.9
| | | | Black NR
| | | | Asian 8.6%
| | | | Aboriginal 1%
Morales, 1994 ^67^ (4) | Target | Penult.PTD from PTL or PPROM | University, Baltimore, US | Black 47.5% | 24.8 | Hx >1 PTD in 50% Tx, 39% C | 80/94 | Amsel (<=20) | Oral metronidazole 250mg TID 7d | No | 39.0 | 18.1
Odendaal, 2002 ^58^ (3)^‡^ | Target | Hx PTD or midtrimester abortion | South Africa, NOS | NR | 27.5 | — | 121/127 | Gram stain + Amsel (15 to 26) | Oral metronidazole 400mg BID 2d | Yes | 24.0 | 42.9
Vermeulen, 1999 ^68^ (4) | Target | Penult.PTDs/PPROM | 12 city hospitals in the Netherlands | NR | 31.1 | Hx>1 PTD in 8% Tx, 8% C | 16/22 | Gram stain (>20) | Vaginal clindamycin 7d | Yes | — | —

* The data for race, age, and marital status reflect the total population in each study, which may include women without BV or history of PTD.

† Carey 2000 and McDonald 1997 performed subgroup analyses of high-risk BV-positive women. These women are included in the total population of average-risk women in these respective studies.

‡ Odendaal 2002 included two distinct populations: low-risk women (i.e. primigravidae) and high risk women (i.e. history of PTD or other risk factor).

§ Includes BV-positive and BV-negative women.

Abbreviations: Penult.=penultimate pregnancy; PTD = spontaneous preterm delivery; Hx PTD = history of spontaneous preterm delivery in any prior pregnancy; PTL = idiopathic preterm labor; Tx=Treatment; C=Control

— data not reported

### Summary

Seven new randomized controlled trials were found in the area of treatment of asymptomatic pregnant women with BV since the previous report was published in 2001. When new and 2001 report trial data were pooled, meta-analysis showed there were no treatment effects for women asymptomatic for BV at any risk level (Figures 2–4). We did not pool the PTD <37 weeks, LBW or PPROM outcome data from high-risk patients due to significant heterogeneity among the trials and inconsistency in the direction of treatment effect. For PTD <37 weeks, three of the five trials reported a significant treatment benefit, while one showed significant treatment harm, and the other showed no benefit.

## Key Question 3. What Adverse Effects Does the Screening and/or Treatment of Bacterial Vaginosis Have on Pregnancy Outcomes?

### Adverse Effects of Screening

No studies addressed the adverse effects of screening.

### Adverse Effects of Treatment

Adverse outcomes in BV-negative women. In two studies identified in the previous review, significantly more adverse pregnancy outcomes occurred among BV-negative women who received treatment for BV compared with BV-negative women who were not given antibiotics. ^66,^ ^68^ Preterm delivery prior to 34 weeks occurred more frequently in the BV-negative group in both studies, and one study also reported a greater frequency of neonatal sepsis. ^68^ The current review identified one study conducted in fetal-fibronectin-positive (FFN-positive) women, in which 446 BV-negative women were randomized to receive metronidazole (250mg TID, 10 days) plus erythromycin (250mg QID, 10 days) or placebo. ^69^ Among FFN-positive/BV-negative women in this study, spontaneous PTD <37 weeks occurred more frequently in the treatment group compared with placebo (13.1% vs. 10.6%), but the increase was not statistically significant.

Prenatal Exposure to Metronidazole. The previous review reported that two meta-analyses of metronidazole treatment of case-control and cohort studies found no evidence for teratogenesis, with summary ORs of 1.02 and 1.08 (95%CI 0.98–1.27). ^1^ Recent observational studies similarly found no association between metronidazole and congenital abnormalities. ^70^ – ^72^

A retrospective cohort study determined cancer incidence in children who were exposed prenatally to metronidazole. ^73^ The cohort included children younger than 5 born to women enrolled in Tennessee Medicaid during pregnancy, and the analysis adjusted for maternal age, race, marital status, education, county of residence, and whether the child was first born. The study found no increase in total cancer risk, but did observe an elevated risk for neuroblastomas (RR 2.6, 95%CI 0.89–1.82) that, though not statistically significant, may warrant further study.

All randomized controlled treatment trials discussed in KQ2, published post 2000, were reviewed for any adverse treatment effects data. Three of the trials ^58,^ ^59,^ ^61^ did not provide any data on adverse treatment effects beyond pregnancy outcomes previously highlighted in the KQ2 section. One trial ^21^ stated that none of the patients reported adverse reactions to treatment. Another trial reported an adverse fracture event, however, study group status could not be determined. ^62^

Tolerability. One study provided data on treatment tolerability. ^22^ In a trial of vaginal clindamycin, vulvovaginal itching occurred with similar frequency in the treatment group (3.21%) as in the placebo group (3.19%). ^22^

A recent trial with oral clindamycin (N=485) ^74^ included women with abnormal intermediate flora (Nugent score 4–6), as well as those diagnosed with Bacterial Vaginosis. Discontinuation of therapy due to side effects occurred more frequently with clindamycin than with placebo, but the difference was not statistically significant (7% v. 3%, p=0.10). Reports of side effects in this study included gastrointestinal upset (10 placebo, 5 clindamycin), rashes (1 placebo, 1 clindamycin), vulvovaginal candidiasis (1 placebo, 1 clindamycin), throat irritation (1 placebo) and headaches (1 placebo, 4 clindamycin).

The tolerability of oral and vaginal metronidazole formulations was assessed in a study of cervical cytokine response in BV-positive pregnant women. ^75^ The study reported that subjects tolerated the medications well, with high levels of compliance for both formulations of the drug.

### Summary

No studies addressed the adverse effects of screening. The effects of treatment on women incorrectly diagnosed to have BV have been indirectly studied. The previous review describes two studies of BV-negative women who received treatment for BV compared with BV-negative women who were not given antibiotics, and found an increased frequency of PTD <34 weeks in the BV-negative group in both studies. A new study found that among FFN-positive/BV-negative women, there was a non-significant increase in spontaneous PTD <37 weeks in the treatment versus placebo group.

Recent observational studies confirm findings from the 2001 report of no association between metronidazole and congenital abnormalities. A retrospective cohort study of children exposed prenatally to metronidazole showed mixed results for cancer outcomes and may warrant further study. A number of new treatment studies reported on medication tolerability. There were no statistically significant differences between oral and vaginal clindamycin treatment and control groups, and oral and vaginal metronidazole showed high compliance and tolerability.