# Methods

## Literature Search and Strategy

We conducted literature searches relevant to our critical key questions (Appendix A). All citations and articles were managed in an electronic database (Endnote^®^). Searches were conducted in the Cochrane Central Database of Controlled Trials, the Cochrane Database of Systematic Reviews, and the Database of Abstracts of Reviews of Effects through the 2^nd^ quarter of 2006 to identify studies relevant to the critical key questions. The Ovid MEDLINE Database of In-Process and Other Non-Indexed Citations was searched from January 2000 to July 2006 to identify otherwise non-indexed studies relevant to any critical key question. In addition, key question specific searches were conducted for key questions 1, 2, and 3 in Ovid MEDLINE from January 1996 to July 2006.

We identified 8 systematic reviews^34^–^41^and used those systematic reviews as sources of relevant randomized controlled trials for this review. In addition to the list obtained through database searching, articles were also obtained by comparing reference lists of reviews, studies, editorials, reports, and websites; and by consulting experts.

## Inclusion and Exclusion Criteria

Investigators dually reviewed abstracts identified by the searches and papers identified as described above for potential relevance to all critical key questions, and determined eligibility by applying inclusion and exclusion criteria (Appendix B). Eligible studies related to the screening and treatment key questions were conducted in settings where pregnant women went for prenatal and obstetric care. These settings included both university-based and non-university-based obstetric and hospital clinics. Systematic reviews and individual randomized controlled trials that evaluated screening and/or treatment pregnancy outcomes and/or adverse effects for asymptomatic women with bacterial vaginosis (BV) were reviewed. Participants included pregnant women at low, average, or high risk for preterm delivery. Eligible studies were in the English language and conducted in the U.S. or a developed country.^48^ Studies of non-pregnant women, studies lacking pregnancy outcomes, studies of poor quality, and animal studies were excluded (Appendix C). Studies where excluded if the focus of the study was multiple infections and data was not available for the BV group only. A “best evidence” approach was applied, in which studies with the highest quality and most rigorous design are emphasized.^49^

## Critical Appraisal

Two reviewers independently rated the quality of studies using design-specific criteria developed by the USPSTF^50^ and Jadad^51^ (Appendix D). Reviews were not excluded based on quality, as searching for individual trials within these reviews was our priority. The overall rating for each individual study is a combination of internal and external validity scores. When reviewers disagreed, a final rating was reached through consensus. Good or fair quality individual randomized controlled trials are emphasized in this report.

## Size of Literature Reviewed

A total of 570 unique citations (Appendix E) were identified from the literature searches, the previous report, reference lists, and through expert referrals. Two hundred nine abstracts were reviewed to identify literature showing direct evidence of screening related to reduced adverse pregnancy outcomes, of which none met the inclusion criteria (KQ 1). Two hundred thirteen abstracts were reviewed to identify literature showing evidence that treatment reduces adverse pregnancy outcomes, of which 7 randomized controlled trials, and 8 systematic reviews that were used for source documents, met the inclusion criteria (KQ 2). Seventy-four abstracts were reviewed to identify literature showing evidence whether there are adverse effects associated with screening and/or treatment of bacterial vaginosis on pregnancy outcomes, of which 9 met the inclusion criteria (KQ 3). One hundred seventy-eight additional abstracts from keyword searches were reviewed for applicability to any of the questions, and then combined with the appropriate questions. (Seven treatment trials and 5 adverse effects studies from the 2001 report will be synthesized with the new evidence).

## Data Synthesis

Data from the full text of the original articles and systematic reviews were abstracted to evidence tables. The data included study, year, setting, patient demographics, inclusion/exclusion criteria, and risk status. Pregnancy outcome data included completed weeks of gestation at delivery, preterm premature rupture of membranes (PPROM), neonatal death, and other pregnancy outcomes if provided. Abstracted treatment data included gestational age (in weeks) at screening/treatment, type of treatment, dose, regimen, administration route, number of treatment rounds, and adverse effects. Data on the percentage of adverse pregnancy outcomes in the BV-positive treatment group and percentage of adverse pregnancy outcomes in the BV-positive placebo group were also abstracted. Summary tables with specific information were then developed for use of the team in evidence synthesis and by the statistician to provide further analysis of the data.

## Statistical Analysis

We performed a series of meta-analyses that included trials located for this review and the previous review to estimate the effect of treatment on preterm delivery (<37 weeks, <34 weeks, or <32 weeks), on LBW, and on PPROM. The primary measure of effect of BV treatment was the difference in proportions of pregnancy outcomes between the control and treatment group, the absolute risk reduction (ARR) [Control - Treatment]. A zero would indicate no treatment effect, or no differences between the treatment and control groups for adverse pregnancy outcomes. A negative ARR favors placebo, where reduced adverse pregnancy outcomes are evident for those not being treated. A positive ARR favors treatment where those being given the treatment show less adverse pregnancy outcomes. For each study, the absolute risk reduction (ARR), and its standard error was calculated and used as the measure for the effect of treatment. Analysis was stratified by risk group (low, average or high risk group) and studies were pooled when appropriate to provide a combined estimate of ARR and its 95% confidence intervals (CI). If there was evidence of heterogeneity among trials at a significance level of P = .10 based on the standard chi-square test for heterogeneity, we used a random effects model.^54^ To address the effect of quality of trials, we performed a sensitivity analysis by excluding poor quality trials with a Jadad score ≤ 2.

We also assessed publication bias by using funnel plots and Egger's linear regression method.^55^ No publication bias was detected by these methods, however, their interpretation is limited by the small numbers of trials for each therapy.^56^ All analyses were performed using Stata version 9.0 (StataCorp LP, College Station, Tex).

## Summary of Benefits and Harms

To provide a clinical interpretation of the results, estimates derived from the meta-analysis and systematic reviews of studies of screening for BV were used to construct an updated balance sheet that summarizes the benefits and harms of screening for BV in 1,000 high-risk women.^57^

## External Review Process

The USPSTF appointed the author of the previous systematic review to advise the Oregon Evidence-based Practice Center in formulating and reporting this update. An additional set of outside experts (see Appendix F) provided advice on a draft version of the evidence synthesis, presented at the July 13–14, 2006 Task Force Meeting. The feedback was fully incorporated into the final report.