# Introduction

## Preface

Systematic evidence reviews serve as the basis for U.S. Preventive Services Task Force (USPSTF) recommendations on new clinical prevention topics. The USPSTF tailors the scope of these reviews to each topic.

The USPSTF last reviewed screening for bacterial vaginosis (BV) in 2001. Using the review prepared by Guise and colleagues^1,^ ^2^ the USPSTF decided to recommend against routinely screening average-risk asymptomatic pregnant women for bacterial vaginosis (BV) with a D recommendation. The USPSTF also concluded that the evidence is insufficient to recommend for or against routinely screening high-risk pregnant women for BV with an I recommendation. Clinical considerations for populations at high risk were also provided.^3^

The USPSTF made the update of the BV topic a priority for 2006. Gaps in evidence evident from the prior recommendation included information that would make it possible to characterize the patients most likely to benefit from screening, evidence about the optimum timing of screening and treatment, information to determine the effect of treatment on pregnancy outcomes, the fact that the screening methods used in research do not reflect those used in practice, and the fact that the findings of studies in U.S. health clinics are not generalizable to community-based practices.

## Condition Definition

Bacterial vaginosis (BV) is the most common lower genital tract syndrome among women of reproductive age.^4^ It involves an imbalance in the vaginal bacterial ecosystem such that hydrogen peroxide-producing lactobacilli are diminished and Gardnerella vaginalis, anaerobes, and mycoplasmas are abundant. Symptoms include vaginal discharge, pruritus, or malodor; however, approximately half of women with BV are asymptomatic.^5^–^7^ Once diagnosed, the microflora imbalance can be altered with a short course of antibiotic therapy.

## Prevalence and Burden of Disease

For two decades now, researchers have documented the associations between BV and adverse pregnancy outcomes focusing on preterm birth and timing of treatment.^7^–^16^ This epidemiologic evidence has been used as a rationale for screening asymptomatic pregnant women for BV.

Most data on the prevalence of infection come from academic medical centers or public hospitals. In several large prospective, longitudinal studies performed in these settings, the prevalence of BV has ranged from 9 to 23%.^9^–^11,^ ^17^–^19^ The prevalence of BV in pregnant women seen in community settings is not well studied. BV in pregnancy is more common among African-American women, women of low socioeconomic status, and those who have previously delivered low-birth weight infants.^10,^ ^20^

The recently completed National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network study found that forty-five percent of the African American women in this sample had BV.^15^ In a secondary analysis of 4 prospective studies in Denver, rates of BV and other vaginal infections were significantly higher among Black women than among non-Hispanic white or Asian comparators (39.8 vs. 24.6, respectively).^20^ A predominantly Caucasian sample of 4,429 pregnant women presenting for routine prenatal care in non-hospital-based clinics in Vienna had a 8.6% rate of BV.^21^

The natural history of BV in pregnant women has shown that up to 50% of BV cases resolve spontaneously during pregnancy.^22^–^24^ Whether or not to screen and/or treat multiple times, and when to start and at what interval during pregnancy, are still unanswered questions, as BV may not necessarily persist throughout pregnancy.^22^

## Current Clinical Practice

### Diagnosis

BV is diagnosed using Amsel's clinical criteria or Gram stain. Using Amsel's criteria, the clinical diagnosis is made by fulfilling three out of four criteria: (1) vaginal pH > 4.7, (2) the presence of clue cells on wet mount, (3) thin homogeneous discharge, and (4) amine “fishy odor” when potassium hydroxide is added to the discharge.^5^ Two different Gram stain scoring systems, Nugent's^25^ and Spiegel's^26^ have been developed and compared with Amsel's clinical criteria. Gram stain of vaginal discharge may be a more reliable means of diagnosing BV, and it offers the added ability of quantifying and classifying bacterial load.^1^ For these reasons, Gram stain has been the primary means used to diagnose BV in epidemiologic and treatment studies, with Nugent's criteria accepted as the preferred method.^1^

Gram stain is less commonly used in clinical practice because of the need for laboratory facilities and the consequent delay in receiving diagnostic results. Because most data on pregnancy outcomes and their association with BV and improvement with BV treatment are based on studies that used Gram stain as their diagnostic criteria, a question remains as to whether research findings for pregnancy outcomes can be directly translated into practice.^1^

### Accuracy of Diagnostic Methods in Clinical Versus Research Settings (Subsidiary Question)

Authors of the previous review noted that the preferred diagnostic test would be one that predicts pregnancy outcomes with the most accuracy. The current review identified two publications that evaluated various diagnostic tests in predicting preterm birth: a meta-analysis^27^ and a secondary analysis^28^ of 12,041 women who were screened for the BV Trial,^29^ but not randomized to either metronidazole or placebo therapy.

The secondary analysis of women screened but not randomized for the BV Trial assessed whether there were threshold values of vaginal pH and Gram stain scores in early pregnancy that were linked with subsequent preterm birth.^27^ The meta-analysis included 11 observational studies that tested for BV using Nugent's criteria for Gram staining (7 studies, n=13,729), Spiegel's criteria for Gram staining (2 studies, n=927), or clinical criteria that included microscopy (2 studies, n=3067). The pooled results showed no differences between the various tests in their accuracy for predicting preterm birth. The meta-analysis was limited by the small number of studies that were combined for each test.^27^

The analysis of women screened but not randomized for the BV Trial assessed threshold vaginal pH and Gram stain scores in early pregnancy (8–22 weeks) that were predictive of subsequent preterm birth. Pregnancy outcomes were available for 12,041 of 21,554 women with vaginal pH determined at screening, and for 6,838 of 12,010 women who had both vaginal pH ≥ 4.5 and a Gram stain result. The study found that women with vaginal pH ≥ 5.0 had a significantly increased incidence of subsequent spontaneous preterm delivery (PTD) at <37, <35, and <32 weeks, compared with women with vaginal pH < 5.0 (p<0.0001). Women with vaginal pH >=4.5 and Gram stain scores of 9 to 10 had a higher risk of spontaneous PTD < 37 weeks compared with women having a Gram stain score of 8 or less. The proportion of women with PTD <37 weeks was similar among women with vaginal pH >=5.0 (12.4% of 2759) and women with vaginal pH >=4.5 and Gram score of 9 to 10 (12.6% of 1664).^28^ These results suggest that a higher-risk population may be defined using vaginal pH >=5, or the combination of vaginal pH >=4.5 with Gram score of 9 to 10. The analysis, however, did not directly compare vaginal pH with Gram stain alone in the prediction of spontaneous PTD.

One study^30^ found that using any 2 of 3 clinical criteria (viz. ph >4.5, whiff test positive, and clue cells positive) had a sensitivity of 56%, specificity of 96%, positive predictive value of 83%, and negative predictive value of 85%, compared with Gram stain diagnosis of BV as the standard. False positive rates of the individual clinical components versus Gram stain-based diagnosis were 48% for pH >4.5, 29% for positive whiff test, and 25% for clue cells present on wet smear. The proportion of false positives for the clinical diagnosis overall was 4%, calculated as 1 minus specificity. (The study reported a false positive rate of 17%, apparently calculated as 1 minus positive predictive value. The conventional method for calculating the false positive rate, however, is 1 minus specificity). The authors of the study attributed these findings to the “subjective nature of the clinical test.”^30^ Another study that similarly defined BV on the basis of 2 of 3 clinical signs (ph > 4.5, presence of clue cells, positive whiff test) showed improved sensitivity over Amsel criteria that additionally included appearance of vaginal secretions. (36.3% vs. 63.6%, using Gram stain as the reference). The false positive rate for the modified criteria was 2%.^31^

None of the studies identified by the literature search on the diagnostic accuracy of clinical criteria documented whether clinicians routinely implement all of part of Amsel's clinical criteria in practice. The extent to which research findings would apply to the practice setting therefore remains unclear. Two studies suggested that the presence of clue cells as the sole diagnostic criterion has a false positive rate (i.e., 1 minus specificity) of 6%, and a false negative rate (i.e., 1 minus sensitivity) of 41%^31^ to 50%.^30^

### Treatment

The previous systematic review describes in detail the therapies used for treating BV, recommended dosages during pregnancy. and cure rates.^1^ Oral metronidazole and oral clindamycin, as well as vaginal metronidazole gel or clindamycin cream, are used to treat BV. The Centers for Disease Control and Prevention (CDC) reports that cure rates are 78% to 84% in gynecologic patients taking oral metronidazole 500 mg twice a day for 7 days, 82% for clindamycin 2% vaginal cream once daily for 7 days, and 75% for metronidazole gel twice a day for 5 days.^32^ A systematic review of randomized controlled trials of BV treatment in pregnancy found treatments to be comparable in their effectiveness at eradicating BV.^33^ In pregnancy, oral metronidazole and oral clindamycin are the recommended regimens, with metronidazole gel as an alternative. Citing adverse pregnancy outcomes, the CDC does not recommend using vaginal clindamycin cream during pregnancy. The CDC-recommended treatment for BV in pregnancy is 250 mg oral metronidazole 3 times a day for 7 days 70–4. This lower dosage is recommended to minimize exposure to the fetus.^32^

## Systematic Reviews in the Field

We reviewed 8 systematic reviews and meta-analyses of BV treatment in pregnant women identified by the searches and published since the 2001 report.^34^–^41^ Because the inclusion and exclusion criteria of these systematic reviews and meta-analyses differed from this review, we decided to use these reviews as source documents, and retrieve relevant, original articles from these papers. For instance, a number of reviews included studies where randomization methods were unknown or where details on how risk groups were categorized were not provided. We chose to update this work with the same methods utilized by the 2001 report team.

The majority of the reviews^34^–^36,^ ^38^ report no treatment effect for BV positive, asymptomatic pregnant women, while suggesting that there is a benefit of treatment for patients at high risk for preterm delivery.^34,^ ^38,^ ^39^

## Recommendations from Other Groups

The Centers for Disease Control (CDC),^42^ American College of Obstetricians & Gynecologists (ACOG),^43^ Cochrane Pregnancy and Childbirth Group,^34^ British Association for Sexual Health and HIV (BASHH)/Clinical Effectiveness Group (CEG),^44^ National Institutes of Health (NIH),^45^ American Academy of Family Physicians (AAFP),^46^ and National Institute of Clinical Excellence (NICE)^47^ make similar screening and/or treatment recommendations for pregnant women with BV. All recommend against routine screening for BV in asymptomatic, pregnant women. Regarding women at high risk for preterm delivery, the CDC, ACOG, AAFP, and BASHH state that there may be a group of high-risk women for whom screening and treatment may be beneficial, consistent with prior USPSTF recommendations. In contrast, the NIH recommends screening all women with prior spontaneous preterm delivery. The CDC does not recommend the use of vaginal cream.

## Focused Systematic Review Aims

This report will be used by the USPSTF to update the 2001 recommendation^3^ on screening for bacterial vaginosis in pregnancy. The format and methods of the previous systematic evidence review developed previously by Guise and colleagues^1^ will be used to guide this update. The lead investigator on this 2001 report served as a consultant for this update. The previous review can be viewed at http://www.ahrq.gov/clinic/uspstf/uspsbvag.htm.

## Analytic Framework and Questions

An analytic framework was developed to outline issues and focus the literature search (Figure 1). The analytic framework begins with a population of pregnant women asymptomatic for BV who are at low risk, average risk, or high risk for preterm delivery. Typically, women were considered to be at low risk if they had not had a previous preterm delivery, or other risk factors for preterm delivery (often these were nulliparous women). The average risk category includes women in the general population of pregnant women presenting to the clinic or study site, which would include a mix of low, average, and high risk women. Women were considered to be of high risk if they had a previous preterm delivery due to spontaneous rupture of membranes or spontaneous preterm labor. For the most part, these definitions were used consistently by authors in the papers we reviewed. Asymptomatic patients were defined as those who presented for routine prenatal visits and not for evaluation specifically of vaginal discharge, odor, or itching. Under this definition, asymptomatic could include both patients who were without symptoms and those who were unaware of symptoms. This population was felt to be most reflective of that encountered in everyday practice.

Figure 1. Analytic Framework and Key Questions

Preterm delivery (PTD), the probability of delivery before term (37 weeks), was the primary outcome measure considered in the literature search. Preterm delivery may be further subdivided into “spontaneous” preterm delivery and “indicated” preterm delivery. Spontaneous preterm delivery arises mainly from preterm premature rupture of membranes or preterm labor. Other outcomes considered were low birth weight (LBW) (<2500 grams), preterm premature rupture of membranes (PPROM), preterm labor, spontaneous abortion, postpartum endometritis, neonatal sepsis, and neonatal death.

Specifically, this systematic review updates the evidence from 2001 to the present for the following questions:

### Critical Key Questions

1 Does screening for bacterial vaginosis during pregnancy in asymptomatic women reduce adverse pregnancy outcomes for those at low risk, average, or high risk for preterm delivery?
2 Does treatment of bacterial vaginosis during pregnancy in asymptomatic women reduce adverse pregnancy outcomes for those at low, average, or high risk for preterm delivery?
3 What adverse effects does the screening and/or treatment of bacterial vaginosis have on pregnancy outcomes?

### Subsidiary Question

Also stated as important to explore is the accuracy of the diagnostic methods used to diagnose bacterial vaginosis in the clinical setting as compared with research methods. This question is described in the introduction section of this report.