# Acknowledgements

The authors gratefully acknowledge Andrew Hamilton, MLS, MS for assistance in developing and running search strategies. Oregon Evidence-based Practice Center Director Mark Helfand, MD, MPH; AHRQ Officers Iris Mabry, MD, MPH, and Mary Barton, MD, MPP; and USPSTF leads Kimberly Gregory, MD, MPH, Lucy Marion PhD, RN, and Diana Petitii, MD, MPH, provided valuable guidance and insights. Sarah Baird, MS, provided technical assistance.