# References

1 Chobanian AV, Bakris GL, Black HR, Cushman WC, Green LA, Izzo JL Jr. Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure, et al. National Heart, Lung, and Blood Institute. Seventh report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure. Hypertension. 2003;42:1206-52. [PMID: 14656957]. [pmid: 14656957].
2 Klein R, Klein BE, Moss SE. The relation of systemic hypertension to changes in the retinal vasculature: the Beaver Dam Eye Study. Trans Am Ophthalmol Soc. 1997;95:329-48. [PMID: 9440178]. [pmid: 9440178].
3 Lederle FA, Johnson GR, Wilson SE, Chute EP, Littooy FN, Bandyk D, et al. Prevalence and associations of abdominal aortic aneurysm detected through screening. Aneurysm Detection and Management (ADAM) Veterans Affairs Cooperative Study Group. Ann Intern Med. 1997;126:441-9. [PMID: 9072929]. [pmid: 9072929].
4 Padwal R, Straus SE, McAlister FA. Evidence based management of hypertension. Cardiovascular risk factors and their effects on the decision to treat hypertension: evidence based review. BMJ. 2001;322:977-80. [PMID: 11312234]. [pmid: 11312234].
5 White WB, Lacourciere Y, Gana T, Pascual MG, Smith DH, Albert KS. Effects of graded-release diltiazem versus ramipril, dosed at bedtime, on early morning blood pressure, heart rate, and the rate-pressure product. Am Heart J. 2004;148:628-34. [PMID: 15459593]. [pmid: 15459593].
6 Julius S, Nesbitt SD, Egan BM, Weber MA, Michelson EL, Kaciroti N. Trial of Preventing Hypertension (TROPHY) Study Investigators, et al. Feasibility of treating prehypertension with an angiotensin-receptor blocker. N Engl J Med. 2006;354:1685-97. [PMID: 16537662]. [pmid: 16537662].
7 Ebbs D. A comparison of selected antihypertensives and the use of conventional vs ambulatory blood pressure in the detection and treatment of hypertension. Cardiology. 2001;96(Suppl 1):3-9. [PMID: 11574740]. [pmid: 11574740].
8 Fogari R, Zoppi A, Poletti L, Marasi G, Mugellini A, Corradi L. Sexual activity in hypertensive men treated with valsartan or carvedilol: a crossover study. Am J Hypertens. 2001;14:27-31. [PMID: 11206674]. [pmid: 11206674].
9 Hollenberg NK, Williams GH, Anderson R, Akhras KS, Bittman RM, Krause SL. Symptoms and the distress they cause: comparison of an aldosterone antagonist and a calcium channel blocking agent in patients with systolic hypertension. Arch Intern Med. 2003;163:1543-8. [PMID: 12860576]. [pmid: 12860576].