# Results

The search returned 378 potentially relevant titles, which we entered into a reference database. A total of 341 studies were excluded after title review, 19 studies were excluded after abstract review, and 13 were excluded after full article review. We excluded 253 studies that were not on hypertension, 62 that included a high-risk population, 31 that did not meet study design criteria, 12 that were not from a U.S. population, 8 that were not done in adults, and 7 that had no relevant outcomes. No new studies on the benefits or harms of screening for high blood pressure met our inclusion criteria. Five studies evaluated the harms of early treatment of hypertension and met our inclusion criteria (Table); these are discussed below.

Studies included on harms of early treatment of high blood pressure.*

Author, Year | Study Objective | Sample Characteristics | Inclusion Criteria | Design | Study Groups | Comparison of Groups and Withdrawals | Main Results | Adverse Events | Summary
Fogari et al, 2001 (8) | To evaluate the effects of valsartan and carvedilol on sexual function in men | N = 160 | Newly diagnosed hypertension | RCT | 120 patients received carvedilol or valsartan for 16 wk, followed by 4 wk of placebo; they then “crossed over” to alternative regimen for another 16 wk | 6 patients were lost to follow-up: 2 had hypotension, and 4 in placebo group had hypertension ≥ 110 mm HG | Mean number of intercourse episodes: | Erectile dysfunction: | Carvedilol produced a decline in sexual function (decreased frequency of sexual activity and increased number of patients who had sexual dysfunction).
| | Age = 40–49 y | Men never treated for hypertension | | 40 patients received only placebo | | At 4 wk: reduced by 43% with carvedilol and by 20% with valsartan (p < 0.05) | 15 patients (13.5%) receiving carvedilol | Valsartan produced a temporary, non-significant decline in sexual function and improved function with ongoing treatment.
| | All married | DBP ≥ 95 < 110 mm Hg | | | | At 16 wk: reduced by 50% with carvedilol but increased by 19% with valsartan | 1 patient receiving valsartan and 1 receiving placebo (P < 0.001) | The drugs did not differ in terms of blood pressure control.
| | | No sexual dysfunction
Hollenberg et al, 2003 (9) | To evaluate symptom distress associated with eplerenone compared with amlodipine | N = 269 | Age > 50 y | Randomized Trial | 134 patients received eplerenone | Groups did not differ in age, sex, ethnicity, employment, initial QOL, or baseline BP. | Average decrease in Symptoms Distress Index score with amlodipine and increase in score for eplerenone (P = 0.03); 36 of 73 symptoms favored eplerenone, and 1 favored amlodipine. | No eplerenone side effects related to an action on steroid receptors | Amlodipine was associated with annoying but not life threatening side effects.
| | Mean age: | Men & women | | 135 patients received amlodipine | Dropout rates did not differ by group but were higher for amlodipine (30 patients [25%]) than eplerenone (19 patients [16%]). | No significant differences in SF-36 Health Survey results | No cases of gynecomastia, tender breasts, or menstrual irregularities
| | 67 y - eplerenone group | Untreated SBP 140–190 mm Hg | | Patients were followed for 24 wk | | Amlodipine was significantly associated with ankle swelling, headache, facial flushing, constipation, and pronounced heartbeat. | Edema: 25% with amlodipine versus 5% with eplerenone
| | 69 y - amlodipine group | | | QOL measures at 14 and 24 weeks were: | | Both drugs decreased systolic BP; amlodipine significantly decreased diastolic BP.
| | White: 89% | | | SF-36 Health Survey (8 aspects of health-related QOL†);
| | | | | Symptom Distress Index (73 items);
| | | | | Cantril's Ladder (0–10 ladder grade of QOL)
White et al, 2004 (5) | To determine whether extended-release diltiazem at bedtime is superior to ramipril at bedtime for the control of early morning BP | N=261 | DBP 90–110 mm Hg during run-in placebo period | Multicenter randomized trial in the US and Canada | Extended-release diltiazem, 240, 360, or 540 mg at bedtime | 90% of diltiazem recipients and 92% of ramipril recipients completed the study. | Extended-release diltiazem reduced early morning BP to a greater extent than ramipril (-18/-15 mm Hg vs. -13/-8 mm Hg) (p < 0.001). | ≥1 AE occurred in 50% of diltiazem recipients and 40% of ramipril recipients. | AEs were very common (40–50% of patients) with both drugs.
| | Men: 61% | Patients with history of CAD, stroke, CHF, secondary hypertension, cardiac conduction abnormalities, poorly controlled DM, malabsorption, or CRF were excluded. | | Ramipril, 5, 10, or 20 mg at bedtime | AEs were the most common reason for dropping out. | | No deaths | Serious AEs were uncommon (2%–3%) and 2 of the 3 reported were probably not related to the drug.
| | Mean age: 54 y | | | 2 week pre-study washout of hypertension medications, 3- to 4-week placebo run-in, then 10 wk of treatment | | | [underlined: Withdrawals:]
| | White: 93% | | | | | | 3 patients with serious AE: 1 during placebo run-in,
| | | | | | | | 1 in diltiazem group (facial/peripheral edema),
| | | | | | | | 1 in ramipril group (severe UTI)
| | | | | | | | Most common reason for withdrawal:
| | | | | | | | leg edema with diltiazem (3%)
| | | | | | | | cough with ramipril (2%)
| | | | | | | | [underlined: Other AEs:]
| | | | | | | | [underlined: Ramipril:] cough (8%), HA (12%),
| | | | | | | | Lower-extremity edema (2%)
| | | | | | | | [underlined: Diltiazem:]
| | | | | | | | Cough (0.8%), HA (5%), lower extremity edema (13%)
Julius et al, 2006 (6) | To examine whether treatment of prehypertension with candesartan prevents or postpones stage 1 hypertension | N = 809 | Age 30–65 y | Multicenter double-blind | 1) Placebo for 4 y; 2) Candesartan, 16 mg, for 2 y, then placebo for 2 y | | Candesartan significantly decreased risk for hypertension at the end of 4 y (relative risk, 0.84) | [underlined: Serious AEs:] | AEs were very common: about 89% of participants.
| | Mean age: 48 y | Not receiving treatment for hypertension | RCT in the United States | 3-wk run-in period | | | 3.5% of candesartan recipients, 5.9% of placebo recipients | Serious advents are uncommon: 3.5% of candesartan recipients.
| | Men: 59–60% | Average BP: | | If hypertension developed, patients were given metoprolol or hydrochlorothiazide | | | [underlined: Other AEs:]
| | White: 80%–84% | SBP = 130–139 mm Hg | | | | | 89% of candesartan recipients, 88.5% of placebo recipients
| | Mean BMI: 30 kg/m^2^ | DBP = ≤ 89 mm HG | | | | | [underlined: AEs with higher rate in candesartan vs. placebo:]
| | | | | | | | Headache: 21.5%
| | | | | | | | URI: 14.4%
| | | | | | | | Nasopharyngitis: 10%
| | | | | | | | Dizziness: 10%
| | | | | | | | Fatigue: 8.1%
| | | | | | | | Pain in extremity: 7.6%
| | | | | | | | Insomnia: 5.6%
| | | | | | | | Anxiety: 5.6%
| | | | | | | | Hypotension: 1%
| | | | | | | | Syncope: 0.5%
Ebbs, 2001 (7) | To determine whether ambulatory BP monitoring can assess the effectiveness of selected antihypertensives in maintaining 24-hour BP control | N = 204 | DBP 95–110 mm Hg | Multicenter randomized trial in the United Kingdom | 1) Doxazosin, 1, 2, or 4 mg; 2) Amlodipine, 5 or 10 mg; 3) Enalapril, 5, 10, or 20 mg; 4) Bendrofluazide, 2.5 or 5 mg | | 24-h ambulatory SBP and DBP decreased in all groups; no significant differences among groups. | 74% of participants reported an AE. | AEs were very common (74%); the most common AE was headache.
| | Men: 43–48% | Patients with treatment for hypertension, symptomatic CVD, end-organ damage, secondary or malignant hypertension, intolerance of study medications, hypercholesterolemia, Type I DM, renal impairment, or pregnancy were excluded | | 8 wk placebo run-in period | | | Withdrawals: 11% overall due to an AE | Serious AEs were uncommon (11%).
| | Mean age: 54–58 y | | | Treatment for up to 14 wk and titrated to achieve BP control and then treatment for another 8 wk | | | Most common AE: headache (20%)
| | White: 99%
| | Mean BP:
| | Mean SBP, 152–161 mm Hg
| | Mean DBP, 97–100 mm Hg

* Abbreviations: AE = adverse effects; BMI = body mass index; BP = blood pressure; CAD = coronary artery disease; CHF = congestive heart failure; CRF = chronic renal failure; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; HA = headache; QOL = quality of life; RCT = randomized controlled trial; SBP = systolic blood pressure; SF-36 = Short Form-36; URI = Upper respiratory infection; UTI = urinary tract infection.

† The 8 aspects of health-related QOL are: physical functioning, role-physical, bodily pain, general health, vitality, social functioning, role-emotional, and mental health.

Three studies presented data on adverse effects related to antihypertensive drugs. These studies compared outcomes from treatment of one type of drug versus another type of drug or placebo. In general, they were multicenter studies in the United States, Canada, and United Kingdom; included a predominantly white, male patient sample; and excluded persons with multiple comorbid conditions or manifest cardiovascular disease. In addition, two studies examined the effects of antihypertensive medications on quality of life. In these 2 studies, participants with untreated hypertension were randomly allocated to different treatment regimens (the second study also included a placebo group) and followed for effects on quality of life: sexual dysfunction in one study, and “symptom distress” in the other study. The study on sexual dysfunction included men 40 to 49 years of age, and the study on symptom distress included men and women 50 years of age or older.

In 1 study that gathered data on adverse effects, White and colleagues studied the effect of bedtime dosing on early morning blood pressure in 261 persons who were randomly allocated to 10 weeks of extended-release diltiazem or ramipril (5). Adverse effects were reported in 50% of the diltiazem group and 40% of the ramipril group. Serious adverse effects were uncommon, and 2 of the 3 reported events were probably not related to the drug: 1 event occurred during placebo run-in, and 1 was associated with infection. The most common reasons for withdrawal from the study were lower-extremity edema associated with diltiazem (3%) and cough associated with ramipril (2%). Headache was commonly reported in both groups. The main finding of the study was that diltiazem at bedtime reduced early morning blood pressure to a greater extent than ramipril.

Julius and colleagues compared candesartan with placebo in participants with systolic blood pressure of 130 to 139 mm Hg and diastolic blood pressure of 89 mm Hg or less." (6). Serious adverse effects were uncommon: 3.5% of candesartan recipients and 5.9% of placebo recipients. However, other, less serious adverse effects were very common, occurring in approximately 89% of participants in both the candesartan and placebo groups. Commonly reported adverse effects in the candesartan group were headache (22%), upper respiratory infection (14%), nasopharyngitis (10%), and dizziness (10%).

A third study evaluated the effectiveness in reducing clinic-measured and ambulatory blood pressure of 4 antihypertensive agents (doxazosin, amlodipine, enalapril, and bendrofluazide) in 204 persons with diastolic blood pressure of 95 to 110 mm Hg (7). The authors reported that clinic-measured and ambulatory blood pressure decreased in all groups, with no significant differences among the 4 groups; the authors did not report data that allowed us to determine the statistical significance of this comparison. Adverse effects were very common and did not statistically significantly differ among treatment groups (overall rate, 74%; range among groups, 68% to 81%). Serious adverse effects were uncommon (overall rate, 11%; range, 6% to 14%), and the rate of withdrawals due to adverse events was 11%. The most commonly reported adverse effect was headache (overall rate, 20%; range, 16% to 25%).

In 1 study with quality-of-life outcomes, Fogari and colleagues followed 160 married men 40 to 49 years of age with newly diagnosed hypertension (diastolic blood pressure of 95 to 110 mm Hg) who had never been treated for hypertension and had no symptoms of sexual dysfunction (8). One hundred twenty men were randomly assigned to receive an angiotensin II receptor antagonist (valsartan) or a β-blocker (carvedilol) for 16 weeks, and, after a placebo washout period, were crossed over to the alternative regimen for another 16 weeks; 40 men were randomly assigned to receive placebo. Results indicated that carvedilol caused a decline in sexual function (the rate of sexual intercourse decreased by 50%, and 13.5% of patients experienced sexual dysfunction). Valsartan produced a temporary and non-statistically significant decline in sexual function, and function improved with ongoing treatment: By 16 weeks, the rate of sexual intercourse had increased by 19%. The 2 drugs did not differ in control of blood pressure.

The other study with quality-of-life outcomes evaluated symptom distress associated with a calcium-channel blocker (amlodipine) and an aldosterone receptor antagonist (eplerenone) (9). A total of 269 men and women 50 years of age or older with untreated seated systolic blood pressure of 140 to 190 mm Hg were randomly assigned to receive one of the study drugs after a placebo run-in period. On average, participants were approximately 68 years of age, and 89% were white. Participants were followed for 24 weeks; quality-of-life measures were collected at randomization, 14 weeks, and 24 weeks. At 24 weeks, the groups did not statistically significantly differ in blood pressure control or scores on the Short Form-36 Health Survey. However, there was a statistically significant difference among treatment groups on a summary measure of symptom distress in favor of eplerenone (P = 0.03). The amlodipine group experienced symptoms commonly associated with the drug, including ankle swelling, headache, facial flushing, and constipation. Twenty-five percent of amlodipine recipients and 5% of eplerenone recipients experienced edema. Other adverse events were hyperkalemia in 2 eplerenone recipients and 1 amlodipine recipient, and hypokalemia in 2 amlodipine recipients. Erectile dysfunction was reported by 2 of 61 eplerenone recipients and no amlodipine recipients.