# Role of the Funding Source

The work of the USPSTF is supported by the Agency for Healthcare Research and Quality. No separate funding was used specifically for this study.