# Data Synthesis and Analysis

Data from the included studies were synthesized qualitatively in tabular and narrative formats.