# Study Selection

In this review, we included studies on benefits and harms of screening and treatment of “early hypertension.” We understood “early hypertension” to be a blood pressure elevation that screening could reasonably identify. For this review, we defined “early hypertension” as prehypertension (systolic blood pressure of 120 to 139 mm Hg or diastolic blood pressure of 80 to 89 mm Hg), hypertension detected through screening, or untreated or newly diagnosed mild to moderate hypertension (systolic blood pressure of 140 to 180 mm Hg or diastolic blood pressure of 90 to 110 mm Hg, when information was not given about how hypertension was detected). We excluded studies in very high-risk or special populations, including patients with preexisting cardiovascular disease\.

We included studies of non-pregnant adults older than 18 years. We included studies from the United States and from countries with patient populations that are generalizable to the United States. For the literature on benefits, we included meta-analyses; systematic reviews; and randomized, controlled trials. For harms, we included meta-analyses; systematic reviews; randomized, controlled trials; cohorts; case—control studies; and case series of large, multisite databases. We excluded editorials, case reports, nonsystematic reviews, and guideline reports.