# Data Sources and Searches

We performed nonsystematic literature searches of PubMed and the Cochrane Library. We used the following search terms: hypertension, mass screening, adverse effects, and false positive results. We limited the searches to English-language studies of adult humans (age >18 years) that were published in core clinical journals between 1 October 2001 and 31 March 2006. “Core clinical journals” are a subset of 120 English language journals defined by the National Library of Medicine; it was previously known as the Abridged Index Medicus. We also checked reference lists of systematic reviews and other studies for possibly relevant studies.