# Methods

The USPSTF developed 2 key questions to be addressed: 1) What are the benefits of screening for high blood pressure in adults? 2) What are the harms of screening and/or early treatment of high blood pressure? To determine whether the benefits of screening for hypertension continue to outweigh the harms, the USPSTF included new information on the adverse effects of drug therapy for “early hypertension” as part of the question on harms.