# Introduction

Hypertension is usually defined in adults as systolic blood pressure of 140 mm Hg or higher or diastolic blood pressure of 90 mm Hg or higher (1). Data from NHANES III (the Third National Health and Nutrition Examination Survey) suggest that an estimated 43 million U.S. adults older than 25 years have hypertension and that hypertension is more common in African American and elderly persons than in other groups. In the United States, hypertension is responsible for 35% of myocardial infarctions and strokes, 49% of episodes of heart failure, and 24% of premature deaths. Additional complications of hypertension include end-stage renal disease, retinopathy, and aortic aneurysm (2–4).

In 2006, the U.S. Preventive Services Task Force (USPSTF) decided to reexamine the evidence in order to reaffirm its 2003 recommendation on screening for high blood pressure (or hypertension). The Task Force issues a reaffirmation update for a topic that the USPSTF decides to keep current because the topic is one of its priorities, is within its scope, and is a topic for which there is a compelling reason to make a recommendation. Topics in this category are well-established evidence-based standards of current medical practice. The USPSTF decided to perform a reaffirmation update because the evidence base on hypertension is strong and only large, high-quality studies would overturn such a recommendation. Such recommendations would previously have been an A or D recommendation. Therefore, we performed a literature search for new, substantial evidence that would be sufficient to change the 2003 recommendation.