# References

1 U.S. Preventive Services Task Force. Screening for Hemoglobinopathies. In: Guide to Clinical Preventive Services. 2nd ed; 1996:485–94.
2 Newborn screening for sickle cell disease and other hemoglobinopathies. Natl Inst Health Consens Dev Conf Consens Statement 1987;6(9):1–8
3 Gaston MH, Verter JI, Woods G, et al. Prophylaxis with oral penicillin in children with sickle cell anemia. A randomized trial. N Engl J Med. 1986;314(25):1593-9. [pmid: 3086721].
4 Lees CM, Davies S, Dezateux C. Neonatal screening for sickle cell disease. Cochrane Database Syst Rev 2000(2):CD001913.
5 Hirst C, Owusu-Ofori S. Prophylactic antibiotics for preventing pneumococcal infection in children with sickle cell disease. Cochrane Database Syst Rev 2002(3):CD003427.
6 Laird L, Dezateux C, Anionwu EN. Neonatal screening for sickle cell disorders: what about the carrier infants?. Bmj. 1996;313(7054):407-11. [pmid: 8761233]. [pmcid: 2351830].
7 Oliver S, Dezateux C, Kavanagh J, Lempert T, Stewart R. Disclosing to parents newborn carrier status identified by routine blood spot screening. Cochrane Database Syst Rev 2004(4):CD003859.
8 Green JM, Hewison J, Bekker HL, Bryant LD, Cuckle HS. Psychosocial aspects of genetic screening of pregnant women and newborns: a systematic review. Health Technol Assess 2004;8(33):iii, ix–x, 1–109.
9 American College of Medical Genetics. Newborn screening: toward a uniform screening panel and system. In; 2006.
10 Kaye CI, Accurso F, La Franchi S, et al. Newborn screening fact sheets. Pediatrics. 2006;118(3):e934-63. [pmid: 16950973].
11 NHS Sickle Cell and Thalassemia Screening Programme. Standards for the linked antenatal and newborn screening programme. In; 2006.
12 National Institutes of Health. The Management of Sickle Cell Disease, 4th Ed. revised June 2002. NIH National Heart, Lung and Blood Institute. NIH Publication No. 02-2117. http://www.nhlbi.nih.gov/health/prof/blood/sickle/sc_mngt.pdf. Accessed August 2, 2007.
13 Kai J. Details of HTA project in progress: Communication of carrier status information following newborn screening: descriptive study of current practice, methods and experience In: NHS Health Technology Assessment Programme; 2007.
14 Daniel YA, Turner C, Haynes RM, Hunt BJ, Dalton RN. Rapid and specific detection of clinically significant haemoglobinopathies using electrospray mass spectrometry-mass spectrometry. Br J Haematol. 2005;130(4):635-43. [pmid: 16098080].
15 Halasa NB, Shankar SM, Talbot TR, et al. Incidence of invasive pneumococcal disease among individuals with sickle cell disease before and after the introduction of the pneumococcal conjugate vaccine. Clin Infect Dis. 2007;44(11):1428-33. [pmid: 17479937].
16 Grosse SD, Olney RS, Baily MA. The cost effectiveness of universal versus selective newborn screening for sickle cell disease in the US and the UK: a critique. Appl Health Econ Health Policy. 2005;4(4):239-47. [pmid: 16466275].
17 Rogers ZR, Buchanan GR. Bacteremia in children with sickle hemoglobin C disease and sickle beta(+)-thalassemia: is prophylactic penicillin necessary?. J Pediatr. 1995;127(3):348-54. [pmid: 7658261].