# Conclusion

In summary, we found no substantial new evidence since 1996 on the benefits or harms of screening for hemoglobinopathies in newborns. Future research is needed to identify counseling practices that minimize negative psychosocial effects of communicating newborn carrier status information and to develop alternative screening methods that are capable of identifying only clinically significant hemoglobinopathies.