# Emerging Issues and Research Gaps

There is a paucity of research on the psychosocial effects of communicating newborn carrier status information to parents or on which counseling practices are most likely to minimize harmful effects. A descriptive study of current communication practices in the U.K. is underway, with results expected in 2008.^13^

While screening for hemoglobinopathies in newborns is mandated in all 50 states and the District of Columbia, the methods used for initial screening differ. Most states use thin-layer isoelectric focusing (IEF) or high-performance liquid chromatography (HPLC) as their primary screening method, but a few continue to use electrophoresis or DNA testing. Consensus is lacking as to the optimal screening technique. Also, laboratories differ in which hemoglobin variants they commonly report. There is ongoing research into using newer techniques such as mass spectrometry-mass spectrometry (MSMS) to detect only clinically significant hemoglobinopathies, and thereby avoid the problem of what to tell parents of newborns with unidentified hemoglobin variants found incidentally on screening.^14^

The availability of pneumococcal vaccine has altered the calculation of benefits and harms. Starting in 2000, universal childhood vaccination with a 7-valent pneumococcal conjugate vaccine beginning at 2 months of age has resulted in a sharp decline in invasive pneumococcal disease in all children, including those with sickle cell anemia.^15^ Although the vaccine is not completely protective and thus does not obviate the need to give prophylactic penicillin to infants with sickle cell anemia, it has had the effect of making universal newborn screening significantly less cost-effective in comparison to selective newborn screening than in years past.^16^

Although the ACMG core panel^9^ and the NHLBI guideline^12^ recommend prophylactic penicillin for children younger than 5 years of age with hemoglobin SC disease, it is uncertain if these patients require prophylaxis because they were not included in the RCT that established benefit. Compared to hemoglobin SS disease, hemoglobin SC disease is characterized by a mild anemia and preserved splenic function. Citing reports that children with hemoglobin SC have a higher incidence of bacteremia, the NHLBI guideline asserts that “protection of SCD-SC patients with prophylactic penicillin and antipneumococcal vaccine is probably wise even without experimental data.”^12^ This opinion, however, is not universal among sickle cell experts.^17^