# Recent Recommendations from Other Groups

In May 2006, an expert group on newborn screening convened by the Maternal and Child Health Bureau (MCHB) and the American College of Medical Genetics (ACMG) included hemoglobin SS, hemoglobin S/β-thalassemia, and hemoglobin SC disease in its 29-condition uniform newborn screening core panel. The group noted that current screening programs can detect over 700 variant hemoglobins, of which only 25 are considered clinically significant.^9^

In September 2006, the American Academy of Pediatrics revised and updated its Newborn Screening Fact Sheets. The fact sheet on sickle cell disease recommends universal newborn screening and confirmatory testing on a second blood sample, no later than 2 months of age, for infants with initial positive screens.^10^

The United Kingdom's National Health Service (NHS) has established a linked antenatal and newborn screening program for sickle cell disease and thalassemia, and published standards for universal newborn screening in November 2006.^11^

In 2002, the National Heart, Lung and Blood Institute (NHLBI) guideline on management of sickle cell disease affirmed the conclusion of the 1987 NIH Consensus Conference to recommend universal newborn screening. It also noted that “no national consensus has yet been produced to guide neonatal screening programs and clinicians in the followup of infants with unidentified hemoglobin variants.”^12^