# Evidence of the Harms of Screening for Hemoglobinopathies in Newborns

In 1996, the USPSTF observed that false-positive and false-negative screening results are rare in U.S. screening programs.^1^ Since that time, however, screening technology has become capable of identifying several hundred hemoglobin variants, most of negligible clinical significance. Identifying newborns with sickle cell trait - individuals who inherit one copy of hemoglobin S and one copy of hemoglobin A, and are also known as sickle cell carriers - is of uncertain benefit and has the potential to cause psychological harms. Three recent articles have addressed potential harms of disclosing sickle cell carrier status to parents of affected newborns.

Laird and colleagues discussed theoretical concerns raised by notifying parents of their newborn's carrier status, including exposure of non-paternity, stigma and discrimination, negative impact on self-esteem, and anxiety about future health problems. Since, in the United States, withholding carrier status from parents is generally considered to be unethical, access to genetic counseling services is critically important to minimize the risk of these harms.^6^

A 2004 systematic review limited to controlled trials addressing the impact of disclosing newborn carrier status identified by newborn blood spot screening found no eligible studies.^7^ A more comprehensive 2004 systematic review of psychosocial aspects of genetic screening identified two articles, both published prior to 1996, that examined the acceptability of genetic counseling for parents of infants with sickle cell trait. However, neither study described nor attempted to quantify harms resulting from notification of carrier status.^8^ No new studies of health outcomes or psychological harms related to false positive results or communication of carrier status were identified.