# Evidence of the Benefits of Screening for Hemoglobinopathies in Newborns

Thus far, national policies on universal newborn screening for hemoglobinopathies have been based on evidence of the benefits of treatment, in the absence of direct evidence of the value of screening. A national policy was first recommended by a 1987 National Institutes of Health Consensus Conference panel^2^ following the publication of a randomized controlled trial that demonstrated a 84 percent reduction in the incidence of infections in children with hemoglobin SS disease who received prophylactic oral penicillin starting at 4 months of age, compared to children taking placebo.^3^ The 1996 USPSTF recommendation on screening for hemoglobinopathies in newborns was similarly based on an extrapolation of evidence of benefit from early penicillin prophylaxis, rather than evidence of benefit in trials of screening versus no screening.

Our initial literature search identified no new randomized controlled trials of screening for hemoglobinopathies in newborns. A 2000 systematic review of randomized trials comparing diagnosis of sickle cell disease by neonatal screening to clinical diagnosis also found no eligible studies.^4^

A supplemental literature search limited to the Cochrane Database of Systematic Reviews identified a 2002 systematic review of randomized trials comparing prophylactic antibiotics to placebo to prevent pneumococcal infections in children with sickle cell disease. This review included three studies, all of which were published prior to 1996. The review concluded that infants with hemoglobin SS disease who receive prophylactic penicillin have a significantly lower risk for pneumococcal infection (odds ratio = 0.37, 95% CI 0.16 – 0.86) and minimal adverse reactions.^5^