# Introduction

Inherited variants in a recessive gene that encodes the synthesis of a portion of adult hemoglobin (hemoglobin A) produce a spectrum of hemoglobin disorders known as hemoglobinopathies. Individuals who inherit two copies of the variant hemoglobin S develop sickle cell anemia, a chronic disease characterized by an increased risk for invasive infections, recurrent painful crises, and cardiovascular and pulmonary complications. Sickle cell anemia affects 1 out of every 375 African American infants born in the U.S.^1^

In 1996, the United States Preventive Services Task Force (USPSTF) recommended “screening newborn infants for hemoglobinopathies with hemoglobin electrophoresis or other tests of comparable accuracy on umbilical cord or heelstick blood specimens (A recommendation)” in order to “identify infants who may benefit from antibiotic prophylaxis to prevent sepsis.”^1^ The USPSTF also recommended prompt followup for infants identified with sickle cell disease; genetic counseling regarding testing of family members and risks to future offspring; education; and referrals. All 50 states have since instituted universal newborn screening programs for hemoglobinopathies.

In 2007, the USPSTF decided to update its recommendation statement on screening for hemoglobinopathies in newborns. Noting that the 1996 recommendation was made on a strong evidence base and that it would take large, high-quality studies or evidence of substantial harms to overturn the current recommendation, the USPSTF chose to perform a reaffirmation update for this topic. The USPSTF performs reaffirmation updates for older recommendation statements that remain USPSTF priorities, are within the scope of the USPSTF, and for which there is compelling reason for the USPSTF to have a current recommendation statement.

To assist the USPSTF in updating its 1996 recommendation on screening for hemoglobinopathies in newborns, staff at the Agency for Healthcare Research and Quality (AHRQ) performed a literature search and consulted with subject area experts. The goal of this targeted review was to find new, high-quality evidence regarding the benefits and potential harms of screening for hemoglobinopathies in newborns. Sixty-nine studies were initially identified. The literature search methodology is described in Appendix I. One systematic review of benefits of screening, one systematic review of benefits of penicillin prophylaxis, and three articles about potential harms met inclusion criteria and are discussed in the following review.