# Appendix: Literature Search Process for the Reaffirmation Update

AHRQ staff performed a targeted literature search for the benefits of screening for hemoglobinopathies and the potential harms of screening. A baseline search strategy was not available from the 1996 USPSTF recommendation. For this reaffirmation update, searches were limited to the period 1/1/95 to 12/31/06.

Consistent with USPSTF reaffirmation update protocols, initial searches were limited to PubMed core journals. When the initial searches revealed a paucity of eligible articles, the searches were expanded to include non-core journals. Results from PubMed searches were supplemented with recommendations from subject matter experts and reference list reviews.

Since the 1996 USPSTF recommendation was based on strong evidence of benefit from early penicillin prophylaxis, rather than evidence of benefit in a RCT of screening versus no screening, a supplemental search limited to the Cochrane Database of Systematic Reviews was performed to identify new evidence regarding the benefit of prophylactic medication in patients with sickle cell anemia.

All articles were reviewed for predetermined inclusion/exclusion criteria by two team members at each stage of review (title/abstract, full article). A consensus process was used to resolve any reviews which resulted in differences of opinion.

## Basic outline of PubMed search strategies

[underlined: Limited to]: | English
| Human
| Publication Date from 01/01/1995 to 12/31/2006
[underlined: For benefits]
| MeSH terms: “hemoglobinopathies,” “mass screening”
| Limited to: randomized controlled trials, meta-analyses, systematic reviews
[underlined: For harms]
| MeSH terms: “hemoglobinopathies,” “mass screening”
| Other terms: “false positive reactions,” “harms”, “anxiety”
| Excluded: editorials, comments, news items and letters

A series of searches using combinations of MeSH terms and subsets and keyword searches were performed. More details of the search strategies may be obtained from the author.

## Results of the Application of Inclusion/Exclusion Criteria

## Reasons for Exclusion

[underlined: Reason] | [underlined: Description]
Not Newborn (18)* | Study of screening a population other than newborns (eg, pregnant women)
Not Condition(10) | Study not on hemoglobinopathies
Study Design (1) | Study not meeting design inclusion criteria (eg, case report)
No Outcomes (30) | Study or narrative review without information on appropriate hemoglobinopathy-screening-specific harms or benefit outcomes
Not Screening (6) | Study not about screening (eg, treatment of complications)

* Number of excluded studies in parentheses