# Reference List for Evidence Tables

1 Guyer B, Gallagher SS, Chang BH, Azzara CV, Cupples LA, Colton T. Prevention of childhood injuries: evaluation of the Statewide Childhood Injury Prevention Program (SCIPP). Am J Public Health. 1989;79(11):1521-1527. [pmid: 2817165].
2 Kelly B, Sein C, McCarthy PL. Safety education in a pediatric primary care setting. Pediatrics. 1987;79(5):818-824. [pmid: 3554131].
3 Liberato CP, Eriacho B, Schmiesing J, Krump M. SafeSmart Safety Seat Intervention Project: A successful program for the medically-indigent. Patient Educ Couns. 1989;13:161-170.
4 Reisinger KS, Williams AF, Wells JK, John CE, Roberts TR, Podgainy HJ. Effect of pediatricians' counseling on infant restraint use. Pediatrics. 1981;67(2):201-206. [pmid: 7243445].
5 Scherz RG. Restraint systems for the prevention of injury to children in automobile accidents. Am J Public Health. 1976;66(5):451-456. [pmid: 1275118].
6 Alvarez J, Jason LA. The effectiveness of legislation, education, and loaners for child safety in automobiles. Journal of Community Psychology. 1993;21(4):280-284.
7 Serwint JR, Wilson ME, Vogelhut JW, Repke JT, Seidel HM. A randomized controlled trial of prenatal pediatric visits for urban, low-income families. Pediatrics. 1996;98(6):1069-1075. [pmid: 8951255].
8 Christophersen ER, Sullivan MA. Increasing the protection of newborn infants in cars. Pediatrics. 1982;70(1):21-25. [pmid: 7088627].
9 Lindqvist KS. Does the use of child safety seats increase as a result of loan schemes?. Accid Anal Prev. 1993;25(4):421-429. [pmid: 8357455].
10 Reisinger KS, Williams AF. Evaluation of programs designed to increase the protection of infants in cars. Pediatrics. 1978;62(3):280-287. [pmid: 704196].
11 Tietge NS, Bender SJ, Scutchfield FD. Influence of teaching techniques on infant car seat use. Patient Educ Couns. 1987;9(2):167-175. [pmid: 10282837].
12 Barone V. An Analysis of well child parenting classes; The Extent of Parent Compliance with Health Care Recommendations to Decrease Potential Injury of Their Toddlers. University of Kansas, 1988.
13 Goodson JG, Buller C, Goodson WH, III. Prenatal child safety education. Obstet Gynecol. 1985;65(3):312-315. [pmid: 3974957].
14 Gittelman MA, Pomerantz WJ, Laurence S. An emergency department intervention to increase booster seat use for lower socioeconomic families. Acad Emerg Med. 2006;13(4):396-400. [pmid: 16531596].
15 Personal communication, MA Gittleman, March 14, 2006.
16 Stevens MM, Olson AL, Gaffney CA, Tosteson TD, Mott LA, Starr P. A pediatric, practice-based, randomized trial of drinking and smoking prevention and bicycle helmet, gun, and seatbelt safety promotion. Pediatrics. 2002;109(3):490-497. [pmid: 11875146].
17 Macknin ML, Gustafson C, Gassman J, Barich D. Office education by pediatricians to increase seat belt use. Am J Dis Child. 1987;141(12):1305-1307. [pmid: 3687873].
18 Hempel RJ. Intervention to increase seat belt use at a primary care center. The Journal of the American Board of Family Practice / American Board of Family Practice. 1992;5(5):483-487. [pmid: 1414449].