# Appendix E: Inclusion and exclusion of articles from relevant Systematic Evidence Reviews

Table 1 Studies included in 1996 USPSTF report

Article | Status of article in 2006 Update (Included or Excluded*)
Allen DB, Bergman AB. Social learning approaches to health education: utilization of infant auto restraint devices. Pediatrics 1976; 58(3):323–328. | Excluded: Quality-80% attrition
Bass JL, Christoffel KK, Widome M, Boyle W, Scheidt P, Stanwick R et al. Childhood injury prevention counseling in primary care settings: a critical review of the literature. Pediatrics 1993; 92(4): 544–550. | Excluded: More recent SERs used
Berger LR, Saunders S, Armitage K, Schauer L. Promoting the use of car safety devices for infants: an intensive health education approach. Pediatrics 1984; 74(1): 16–19. | Excluded: Quality-50 % attrition
Christophersen ER, Sullivan MA. Increasing the protection of newborn infants in cars. Pediatrics 1982; 70(1): 21–25. | Included
Colquitt M, Fielding LP, Cronan JF. Drunk drivers and medical and social injury. N Engl J Med 1987; 317(20):1262–1266. | Excluded: No behavioral counseling intervention
Greenberg LW, Coleman AB. A prenatal and postpartum safety education program: influence on parental use of infant car restraints. J Dev Behav Pediatr 1982; 3(1):32–34. | Excluded: Quality-52% attrition
Guyer B, Gallagher SS, Chang BH, Azzara CV, Cupples LA, Colton T. Prevention of childhood injuries: evaluation of the Statewide Childhood Injury Prevention Program (SCIPP). Am J Public Health 1989; 79(11):1521–1527 | Included
Kanthor HA. Car safety for infants: effectiveness of prenatal counseling. Pediatrics 1976; 58(3):320–322. | Excluded: Quality-outcome assessment not blinded or standardized
Kelly B, Sein C, McCarthy PL. Safety education in a pediatric primary care setting. Pediatrics 1987; 79(5):818–824. | Included
Kelly RB. Effect of a brief physician intervention on seat belt use. J Fam Pract 1987; 24(6): 630–632. | Excluded: Study Design
Logsdon DN, Lazaro CM, Meier RV. The feasibility of behavioral risk reduction in primary medical care. Am J Prev Med 1989; 5(5):249–256. | Excluded: Quality-groups different at baseline, non-blinded and non-standardized outcome assessment; outcome reported only among at risk population
Macknin ML, Gustafson C, Gassman J, Barich D. Office education by pediatricians to increase seat belt use. Am J Dis Child 1987; 141(12):1305–1307. | Included
Miller JR, Pless IB. Child automobile restraints: evaluation of health education. Pediatrics 1977; 59(6):907–911. | Excluded: Quality-design prone to contamination; analyze all ages together
Reisinger KS, Williams AF, Wells JK, John CE, Roberts TR, Podgainy HJ. Effect of pediatricians' counseling on infant restraint use. Pediatrics 1981; 67(2): 201–206. | Included
Reisinger KS, Williams AF. Evaluation of programs designed to increase the protection of infants in cars. Pediatrics 1978; 62(3):280–287. | Included
Robitaille Y, Legault J, Abbey H, Pless IB. Evaluation of an infant car seat program in a low-income community. Am J Dis Child 1990; 144(1):74–78. | Excluded: Not primary care feasible
Scherz RG. Restraint systems for the prevention of injury to children in automobile accidents. Am J Public Health 1976; 66(5):451–456. | Included
Weinstein ND, Grubb PD, Vautier JS. Increasing automobile seat belt use: an intervention emphasizing risk susceptibility. J Appl Psychol 1986; 71(2):285–290. | Excluded: Not primary care feasible
Worden JK, Flynn BS, Merrill DG, Waller JA, Haugh LD. Preventing alcohol-impaired driving through community self-regulation training. Am J Public Health 1989; 79(3):287–290. | Excluded: Not primary care feasible

* Main reason for exclusion is given. However, a study may have been excluded for more than one reason.

Table 2 Inclusion and exclusion of articles from other relevant systematic evidence reviews

| DiGuiseppi 2000 | Grossman 1999 | ZaZa 2001 | Towner 1996 | Whitlock 2004 | Dinh-Zarr 2005 | Foxcroft 2005 | Status of article in 2006 Update: Included or Excluded*
Anderson P, Scott E. The effect of general practitioners' advice to heavy drinking men. Br J Addict 87 (6):891–900, 1992. | | | | | X | | | Excluded: Does not report designated outcomes
Barone VJ An analysis of well-child parenting classes: The extent of parent compliance with health-care recommendations to decrease potential injury of their toddlers. Dissertation. University of Kansas.1988 (not requested) | X | | | | | | | Included
Bowman JA, Sanson-Fisher RW, Webb GR. Interventions in preschools to increase the use of safety restraints by preschool children. Pediatrics. 1987;79:103–9. | | | X | | | | | Excluded: Not primary care feasible
Chang A, Hearey CD, Gallagher KD, English P, Chang PC. Promoting child passenger safety in children served by a health maintenance organization. Patient Educ Couns 1989; 13(3):297–307. | | X | X | X | | | | Excluded: Quality- non-comparable groups
Christophersen ER, Sosland-Edelman D, LeClaire S. Evaluation of two comprehensive infant car seat loaner programs with 1-year follow-up. Pediatrics 1985; 76(1):36–42. | X | | X | X | | | | Excluded: Quality- 41% attrition
Colletti RB. Hospital-based rental programs to increase car seat usage. Pediatrics 1983; 71(5):771–773. | | X | | | | | | Excluded: Study design
Colletti RB. Longitudinal evaluation of a statewide network of hospital programs to improve child passenger safety. Pediatrics. 1986;77:523–29. | | | X | X | | | | Excluded: Excluded study design
Culler, C and Cunningham, JL. Compliance with the Child Passenger Protection Law: Effects of a Loaner Program for Low Income Mothers. 1980. Washington, D.C, National Highway Traffic Safety Administration. | | | X | | | | | Excluded: Quality- 62% attrition rate
Curry SJ, Ludman EJ, Grothaus LC, Donovan D, Kim E. A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. | | | | | X | | | Excluded: Focus of behavioral counseling not drinking and driving
Fleming MF, Barry KL, Manwell LB, Johnson K, London R. Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA 1997; 277(13):1039–1045. | | | | | X | X | | Excluded: Does not report designated outcomes
Fleming MF, Manwell LB, Barry KL, Adams W, Stauffacher EA. Brief physician advice for alcohol problems in older adults: a randomized community-based trial. J Fam Pract 1999; 48(5):378–384. | | | | | X | X | | Excluded: Does not report designated outcomes
Fleming MF, Mundt MP, French MT, Manwell LB, Stauffacher EA, Barry KL. Brief physician advice for problem drinkers: long-term efficacy and benefit-cost analysis. Alcohol Clin Exp Res 2002; 26(1):36–43. | | | | | | X | | Excluded: Focus of behavioral counseling not drinking and driving
Foss RD. Evaluation of a community-wide incentive program to promote safety restraint use. American Journal of Public Health.79(3):304–6, 1989. | | | X | | | | | Excluded: Did not meet our definition of primary care feasible**
Geddis D, Parent education: its effect on the way children are transported in cars. NZ Med J 1982; 95:314–6 | | X | X | X | | X | | Excluded: Quality- outcomes assessed by interventionist
Geddis DC, Appleton IC. Establishment and evaluation of a pilot child car seat rental scheme in New Zealand. Pediatrics. 1986;77:167–72. | | | X | X | | | | Excluded: Not primary care feasible
Goebel JB, Copps TJ, Sulayman RF. Infant car seat usage. Effectiveness of a postpartum educational program. JOGN. Nurs 1984; 13 (1):33–36. | | | X | | | | | Excluded: Quality- non blinded outcome assessment by interventionists
Goodson JG, Buller C, Goodson WH, III. Prenatal child safety education. Obstet Gynecol. 1985;65:312–15. | | | X | X | | | | Included
Hletko PJ, Hletko J Shelness A Nyberg J. The effect of a toddler/child restraint device rental program on observed correct use. 115–125. 2003. 27th Annual Conference Proceedings, American Association for Automotive Medicine. | | | X | | | | | Excluded: Quality- non-comparable groups
Hletko PJ, Hletko J, Shelness A, Nyberg J. The effect of an in-hospital maternity education program on observed correct crash restraint device use. 1982. Kalamazoo, Michigan, Borgess Pediatric Center, 26th Annual Proceedings, American Association for Automotive Medicine, Ottawa, Ontario, Canada, October 4–6, 1982. | | X | X | | | | | Excluded: Quality- non-comparable groups
Hletko PJ, Robin SS, Hletko JD, Stone M. Infant safety seat use. Reaching the hard to reach. Am J Dis Child. 1987;141:1301–4. | | | X | X | | | | Excluded: Quality- 60% attrition
Jarmark, S, Ljungblom, B, and Turbell, T. Infant carriers - A trial in two counties. 316A. 1988. Linkoping, Sweden, Swedish Road and Traffic Research Institute. | | | X | X | | | | Excluded: Not primary care feasible
Liberato CP, Eriacho B, Schmiesing J, Krump M. SafeSmart Safety Seat Intervention Project: A successful program for the medically-indigent. Patient Educ Couns 1989; 13:161–170. | X | X | X | | | | | Included
Lindqvist KS. Does the use of child safety seats increase as a result of loan schemes? Accid Anal Prev. 1993;25:421–29. | | | X | X | | | | Included
Louis B, Lewis M. Increasing car seat use for toddlers from inner-city families. American Journal of Public Health. 1997;87:1044–45. | | | X | | | | | Excluded: Not primary care feasible
Loveland-Cherry CJ, RossLT, Kaufman SR. Effects of a home-based family intervention on adolescent alcohol use and misuse. J Stud Alcohol Suppl 13:94–102, 1999. | | | | | | | X | Excluded: Not primary care feasible
Manwell LB, Fleming MF, Mundt MP, Stauffacher EA, Barry KL. Treatment of problem alcohol use in women of childbearing age: results of a brief intervention trial. Alcohol Clin Exp Res 2000; 24(10):1517–1524. | | | | | | X | | Excluded: Does not report designated outcomes
Moffit PB. Effects of a child auto restraint education and loan program on restraint use. Dissertation, University of Utah, 1981 | X | | | | | | | Excluded: Quality- non comparable groups; no intention to treat
Nichol KP, Cooney CE. The impact of a hospital-based educational loaner infant car seat program on infant car seat usage in a community. Travel Medicine International 1984; 2(3):155–158. | | X | X | | | | | Excluded: Quality- non-comparable groups
Palinkas LA, Atkins CJ, Miller C, Ferreira D. Social skills training for drug prevention in high-risk female adolescents. Preventive Medicine. 25 (6):692–701, 1996. | | | | | | | X | Excluded: Does not report designated outcomes
Potamianos G, North WR, Meade TW, Townsend J, Peters TJ. Randomised trial of community-based centre versus conventional hospital management in treatment of alcoholism. Lancet 1986; 2(8510):797–799. | | | | | | X | | Excluded: Not a primary care population
Roberts I, Kramer MS, Suissa S. Does home visiting prevent childhood injury? A systematic review of randomised controlled trials. BMJ 1996; 312(7022):29–33. | X | | | | | | | Excluded: Not primary care feasible
Roberts MC, Layfield DA. Promoting child passenger safety: a comparison of two positive methods. J Pediatr Psychol 12:257–271, 1987. | | | X | | | | | Excluded: Did not meet our definition of primary care feasible**
Roberts MC, Turner DS. Rewarding parents for their children's use of safety seats. J Pediatr Psychol 11:25–36, 1986. | | | X | | | | | Excluded: Did not meet our definition of primary care feasible**
Saalberg J, Morrison A. Household Survey. Evaluation of the League General Insurance Company child safety seat distribution program; DOT HS 806 253. Washington, DC: US Department of Transportation; National Highway Traffic Safety Administration; 1982: 63–120. | | | X | | | | | Excluded: Not primary care feasible
Saalberg J, Morrison A. Restraint Use and Injury Experience. Evaluation of the League General Insurance Company child safety seat distribution program; DOT HS 806 253. Washington, DC: US Department of Transportation; National Highway Traffic Safety | | | X | | | | | Excluded: Not primary care feasible
St Pierre TL, Kaltreider DL, Mark MM, Aikin KJ. Drug prevention in a community setting: a longitudinal study of the relative effectiveness of a three-year primary prevention program in boys & girls clubs across the nation. American Journal of Community Psychology. 20 (6): 673–706, 1992. | | | | | | | X | Excluded: Does not report designated outcomes
Stuy M, Green M, Doll J. Child care centers: a community resource for injury prevention. Journal of Developmental & Behavioral Pediatrics 14(4): 224–9. 1993. | | | X | X | | | | Excluded: Not primary care feasible
Tietge NS, Bender SJ, Scutchfield FD. Influence of teaching techniques on infant car seat use. Patient Educ Couns. 1987; 9:167–75. | | | X | | | | | Included
Williams, GE An analysis of well-child parenting classes: An early start to injury prevention. Dissertation, University of Kansas 1988 (not requested) | X | | | | | | | Excluded: Quality- 65% attrition

X = included in listed SER

* May have been excluded for more than one reason.

** Based on description of study in SER; did not review original article