# Appendix A: Literature retrieval process

Figure 1. Search results and article flow

## Search Strategy

Table 1 Search Strategy

KQ 1 & 2 Restraints; 1992 to July 2005 (ML, CCRCT, CDSR, CN, PI, TRIS); 1 Seat Belts/; 2 Automobile restraint$.ti,ab.; 3 Back seat.ti,ab.; 4 Booster seat$.ti,ab.; 5 Car restraint$.ti,ab.; 6 Car safety.ti,ab.; 7 Car seat$.ti,ab.; 8 Carseat$.ti,ab.; 9 Child restraint$.ti,ab.; 10 Child seat$.ti,ab.; 11 Front seat.ti,ab.; 12 Infant restraint$.ti,ab.; 13 Lap belt$.ti,ab.; 14 Rear seat.ti,ab.; 15 Safety belt$.ti,ab.; 16 Safety restraint$.ti,ab.; 17 Safety seat$.ti,ab.; 18 Seat belt$.ti,ab.; 19 Seatbelt$.ti,ab.; 20 Shoulder belt$.ti,ab.; 21 Vehicle restraint$.ti,ab.; 22 belt position$.ti,ab.; 23 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22; 24 health education/; 25 Health promotion/; 26 Mothers/ed [Education]; 27 Behavior therapy/; 28 Counseling/; 29 Directive counseling/; 30 Parents/ed [Education]; 31 Patient education/; 32 Physician's Role/; 33 Student health services/; 34 Teaching Materials/; 35 “Wounds and Injuries”/pc [Prevention & Control]; 36 advice.ti,ab.; 37 advise.ti,ab.; 38 counsel$.ti,ab.; 39 intervention$.ti,ab.; 40 motivational interview$.ti,ab.; 41 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 (379486); 42 23 and 41; 43 limit 42 to english language; 44 limit 43 to (comment or news); 45 43 not 44; 46 limit 45 to yr=“1992 - 2005”
KQ 1 & 3 Riding with alcohol-impaired drivers; 1966 to July 2005 (ML, CCRCT, CDSR, CN, PI, TRIS); 1 passenger$.ti,ab.; 2 riding.ti,ab.; 3 rider.ti,ab.; 4 riders.ti,ab.; 5 1 or 2 or 3 or 4; 6 alcohol.mp.; 7 alcoholic.mp.; 8 drinking.mp.; 9 drinker$.ti,ab.; 10 intoxicate$.ti,ab.; 11 drunk.ti,ab.; 12 impaired.ti,ab. and (driver$ or driving).mp.; 13 6 or 7 or 8 or 9 or 10 or 11 or 12; 14 5 and 13; 15 health education/; 16 Health promotion/; 17 Mothers/ed [Education]; 18 Behavior therapy/; 19 Counseling/; 20 Directive counseling/; 21 Parents/ed [Education]; 22 Patient education/; 23 Physician's Role/; 24 Student health services/; 25 Teaching Materials/; 26 “Wounds and Injuries”/pc [Prevention & Control]; 27 advice.ti,ab.; 28 advise.ti,ab.; 29 counsel$.ti,ab.; 30 intervention$.ti,ab.; 31 motivational interview$.ti,ab.; 32 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 (379486); 33 14 and 32; 34 limit 33 to english language; 35 limit 34 to (comment or editorial or letter or news); 36 34 not 35; 37 from 36 keep 1–71
KQ 1 & 3 Alcohol and driving: 1999 to September 2005 (ML, CCRCT, CDSR, CN, PI, TRIS); 1 Alcohol Drinking/; 2 Alcoholic Intoxication/; 3 Alcoholism/; 4 Drinking Behavior/; 5 alcohol.ti,ab.; 6 alcoholic.ti,ab.; 7 drink.ti,ab.; 8 drinking.ti,ab.; 9 drinker$.ti,ab.; 10 drunk.ti,ab.; 11 intoxicate$.ti,ab.; 12 under the influence.ti,ab.; 13 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 (167771); 14 Accidents, traffic/; 15 Automobile driving/; 16 automobile$.ti,ab.; 17 drive.ti,ab.; 18 driver.ti,ab.; 19 drivers.ti,ab.; 20 driving.ti,ab.; 21 vehicle$.ti,ab.; 22 vehicular$.ti,ab.; 23 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22; 24 Health education/; 25 Health promotion/; 26 Behavior therapy/; 27 Counseling/; 28 Directive counseling/; 29 Patient education/; 30 Physician's Role/; 31 Student health services/ (; 32 Teaching Materials/; 33 advice.ti,ab.; 34 advise.ti,ab.; 35 counsel$.ti,ab.; 36 intervention$.ti,ab.; 37 motivational interview$.ti,ab.; 38 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37; 39 13 and 23 and 38; 40 Accident Prevention/; 41 “Wounds and Injuries”/pc [Prevention & Control]; 42 40 or 41; 43 13 and 42; 44 39 or 43; 45 limit 44 to english language; 46 limit 45 to animals; 47 limit 46 to humans; 48 46 not 47; 49 45 not 48; 50 (news or comment).pt.; 51 49 not 50; 52 limit 51 to yr=“2002 - 2005”; 53 from 52 keep 1–235
KQ 4 Harms: 1996 to September 2005 (ML, TRIS); 1 risk compensation.ti,ab.; 2 risks compensation.ti,ab.; 3 risk homeostasis.ti,ab.; 4 offsetting behavio$.ti,ab.; 5 risk$ driv$.ti,ab.; 6 reckless driv$.ti,ab.; 7 driv$ recklessly.ti,ab.; 8 compensating behavio$.ti,ab.; 9 behavio?r$ compensation.ti,ab.; 10 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9; 11 health education/; 12 health promotion/; 13 mothers/ed; 14 behavior therapy/; 15 counseling/; 16 directive counseling/; 17 parents/ed; 18 patient education/; 19 physician's role/; 20 student health services/; 21 teaching materials/; 22 “wounds and injuries”/pc; 23 advice.ti,ab.; 24 advise.ti,ab.; 25 counsel$.ti,ab.; 26 intervention$.ti,ab.; 27 motivational interview$.ti,ab.; 28 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 (391108); 29 10 and 28; 30 limit 29 to english language; 31 from 30 keep 1–61
Cost: through September 2005 (NHS Economic Evaluation Database); 1 Automobile restraint; 2 Back seat; 3 Booster seat; 4 Car restraint; 5 Car safety; 6 Car seat; 7 Carseat; 8 Child restraint; 9 Child seat; 10 Front seat; 11 Infant restraint; 12 Lap belt; 13 Rear seat; 14 Safety belt; 15 Safety restraint; 16 Safety seat; 17 Seat belt; 18 Seatbelt; 19 Shoulder belt; 20 Vehicle restraint; 21 Belt position; 22 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21; 23 alcohol; 24 drinking; 25 drinker; 26 intoxicate; 27 drunk; 28 impaired; 29 under the influence; 30 23 or 24 or 25 or 26 or 27 or 28 or 29; 31 driver; 32 driving; 33 vehicle; 34 automobile; 35 31 or 32 or 33 or 34; 36 30 and 35; 37 22 or 36; 38 health education; 39 Health promotion; 40 Patient education; 41 Physician's Role; 42 advice; 43 advise; 44 counsel; 45 intervention; 46 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45; 47 37 and 46