# Reference List

1 Subramanian R. Motor vehicle traffic crashes as a leading cause of deth in the United States, 2002. DOT HS 809 831. 2005. Washington, DC, NHTSA's National Center for Statistics and Analysis. Traffic Safety Facts: Research Note.
2 Centers for Disease Control and Prevention (CDC), National Centers for Injury Prevention and Control. Web-based Injury Statistics Query and Reporting System (WISQARS). Center for Disease Control. 2005.
3 National Highway Traffic Safety Administration. Traffic Safety Facts: A Compilation of Motor Vehicle Crash Data from the Fatality Analysis Reporting System and the General Estimates System. DOT HS 809 919. 2004. Washington DC, US Department of Transportation.
4 Blincoe LJ, Seay AG, Zaloshnja E, Miller TR, Romano EO, Luchter S et al. The Economic Impact of Motor Vehicle Crashes, 2000. 2002. Washington, DC, National Highway Traffic Safety Administration. People Saving People. Also available at http://www.nhtsa.dot.gov.
5 Dellinger AM, Langlois JA, Li G. Fatal crashes among older drivers: decomposition of rates into contributing factors. Am J Epidemiol. 2002;155(3):234-241. [pmid: 11821248].
6 Grossman DC. The history of injury control and the epidemiology of child and adolescent injuries. Future of Children. 2000;10(1):23-52. Summer. [pmid: 10911687].
7 Braver ER. Race, Hispanic origin, and socioeconomic status in relation to motor vehicle occupant death rates and risk factors among adults. Accid Anal Prev. 2003;35(3):295-309. [pmid: 12643947].
8 National Highway Traffic Safety Administration. General Child Seat Use Information: Buckle everyone. Children Age 12 and Under in Back! National Highway Traffic Safety Administration. 2005.
9 Kahane C. An Evaluation of Child Passenger Safety: The Effectiveness and Benefit of Safety Seats. National Highway Traffic Safety Administration., editor. DOT HS 806 890. 1986.
10 National Center for Statistics and Analysis. Revised Estimates of Child Restraint Efectiveness. Research Note 1996.
11 Durbin DR, Chen I, Smith R, Elliott MR, Winston FK. Effects of seating position and appropriate restraint use on the risk of injury to children in motor vehicle crashes. Pediatrics. 2005;115(3):e305-e309. [pmid: 15741356].
12 Durbin DR, Elliott MR, Winston FK. Belt-positioning booster seats and reduction in risk of injury among children in vehicle crashes. JAMA. 2003;289(21):2835-40. [pmid: 12783914].
13 Winston FK, Durbin DR, Kallan MJ, Moll EK. The danger of premature graduation to seat belts for young children. Pediatrics. 2000;105(6):1179-1183. [pmid: 10835054].
14 National Highway Traffic Safety Administration. Misuse of Child Restraints. DOT HS 809 671. 2004. Wshington, DC, U.S. Department of Transportation; National Highway Traffic Safety Administration.
15 Kahane C. Fatality Reduction by Safety Belts for Front-Seat Occupants of cars and Light Trucks: Updated at expanded Estimates based on 1986-99 FARS Data. DOT HS 809 199. 2000. Washington, D.C, US Department of Transportation; National Highway Traffic Safety Admnistration.
16 Morgan C. Effectiveness of Lap/Shoulder Belts in the Back Outboard Seating Positions. DOT HS 808 945. 1999. Washington, D.C, US Department of Transportation; National Highway Traffic Safety Admnistration.
17 Dellinger AM, Groff PC, Mickalide AD, Nolan PA. Kids in cars: closing gaps in child occupant restraint laws. Journal of Law, Medicine & Ethics. 2002;30(3 Suppl):150-6.
18 National Highway Traffic Safety Administration., National Center for Statistics and Analysis. Occupant Protection. Traffic Safety Facts 2006.
19 Dinh-Zarr TB, Sleet DA, Shults RA, Zaza S, Elder RW, Nichols JL, et al. Reviews of evidence regarding interventions to increase the use of safety belts. Am J Prev Med. 2001;21(4 Suppl):48-65. [pmid: 11691561].
20 Motor-vehicle safety: a 20th century public health achievement. MMWR Morb Mortal Wkly Rep 1999; 48(18):369–374.
21 Parada MA, Cohn LD, Gonzalez E, Byrd T, Cortes M. The validity of self-reported seatbelt use: Hispanic and non-Hispanic drivers in El Paso. Accident Analysis & Prevention. 2001;33(1):139-43. [pmid: 11189117].
22 Harper JS, Marine WM, Garrett CJ, Lezotte D, Lowenstein SR. Motor vehicle crash fatalities: A comparison of Hispanic and non-Hispanic motorists in Colorado.[see comment]. Annals of Emergency Medicine. 2000;36(6):589-96. [pmid: 11097699].
23 Wells JK, Williams AF, Farmer CM. Seat belt use among African Americans, Hispanics, and Whites. Accid Anal Prev. 2002;34(4):523-529. [pmid: 12067115].
24 Glassbrenner D. Safety belt use in 2004 - demographic results. DOT HS 809 848. 2005. Washington, DC, U.S. Department of Transportation, National Highway Traffic Safety Administration. Research Note.
25 Glassbrenner D. Child restraint use in 2004 - overall results. DOT HS 809 845. 2005. Washington, DC, U.S. Department of Transportation, National Highway Traffic Safety Administration. Research Note.
26 Winston FK, Chen IG, Elliott MR, Arbogast KB, Durbin DR. Recent trends in child restraint practices in the United States. Pediatrics. 2004;113(5):e458-e464. [pmid: 15121989].
27 Hingson R, Winter M. Epidemiology and consequences of drinking and driving. Alcohol Res Health. 2003;27(1):63-78. [pmid: 15301401].
28 U.S. Preventive Services Task Force. Counseling to Prevent Motor Vehicle Injuries. In: Williams & Wilkins, editor. Guide to Clinical Preventive Services. Baltimore: 1996: 643–657.
29 Shults RA, Elder RW, Sleet DA, Nichols JL, Alao MO, Carande-Kulis VG, et al. Reviews of evidence regarding interventions to reduce alcohol-impaired driving. Am J Prev Med. 2001;21(4 Suppl):66-88. [pmid: 11691562].
30 National Highway Traffic Safety Administration., National Center for Statistics and Analysis. Alcohol. Traffic Safety Facts 2004.
31 2005 Roadmap to state highway safety laws: Roadwork ahead: The unfinished safety agenda. HS-043 742, 1–69. 2004. Washington, DC, Advocates for Highway and Auto Safety.
32 Involvement by young drivers in fatal alcohol-related motor-vehicle crashes—United States, 1982-2001. MMWR - Morbidity & Mortality Weekly Report 51(48):1089–91, 2002.
33 Quinlan KP, Brewer RD, Siegel P, Sleet DA, Mokdad AH, Shults RA, et al. Alcohol-impaired driving among U.S. adults, 1993-2002. Am J Prev Med. 2005;28(4):346-350. [pmid: 15831339].
34 National Highway Traffic Safety Administration. National Survey of Drinking and Driving Attitudes and Behavior, 2001. Traffic Tech 2003;(280).
35 Grunbaum JA, Kann L, Kinchen S, Ross J, Hawkins J, Lowry R, et al. Youth Risk Behavior Surveillance—United States, 2003 (Abridged). Journal of School Health. 2004;74(8):307-24. [pmid: 15554117].
36 Centers for Disease Control and Prevention (CDC). Child passenger deaths involving drinking drivers—United States, 1997-2002.[erratum appears in MMWR Morb Mortal Wkly Rep.2004 Feb 13;53(5):109]. MMWR 2004; Morbidity & Mortality Weekly Report. 53(4):77–79.
37 Zuckerman B, Stevens GD, Inkelas M, Halfon N. Prevalence and correlates of high-quality basic pediatric preventive care. Pediatrics. 2004;114(6):1522-1529. [pmid: 15574610].
38 Williams AF, Ferguson SA, De Leonardis DM. Physician counseling about safe vehicle travel for children. [References]. Journal of Safety Research. 2001;32(2):149-156.
39 Rothenstein J, Howard A, Parkin P, Khambalia A, Macarthur C. Community paediatricians' counseling patterns and knowledge of recommendations relating to child restraint use in motor vehicles. Inj Prev. 2004;10(2):103-106. [pmid: 15066976].
40 Ma J, Wang Y, Stafford RS. U.S. adolescents receive suboptimal preventive counseling during ambulatory care. J Adolesc Health. 2005;36(5):441. [pmid: 15841517].
41 Rand CM, Auinger P, Klein JD, Weitzman M. Preventive counseling at adolescent ambulatory visits. J Adolesc Health. 2005;37(2):87-93. [pmid: 16026717].
42 Lin SX, Hyman D, Larson E. Provision of health counseling in office-based practices and hospital outpatient clinics. Prev Med. 2005;40(5):542-546. [pmid: 15749136].
43 Millstein SG, Marcell AV. Screening and counseling for adolescent alcohol use among primary care physicians in the United States. Pediatrics. 2003;111(1):114-122. [pmid: 12509563].
44 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
45 Zaza S, Sleet DA, Thompson RS, Sosin DM, Bolen JC. Reviews of evidence regarding interventions to increase use of child safety seats. Am J Prev Med. 2001;21(4):31-47. [pmid: 11691560].
46 Grossman DC, Garcia CC. Effectiveness of health promotion programs to increase motor vehicle occupant restraint use among young children. American Journal of Preventive Medicine. 1999;16(1S):12-22. [pmid: 9921382].
47 DiGuiseppi C, Roberts IG. Individual-level injury prevention strategies in the clinical setting. Future Child. 2000;10(1):53-82. [pmid: 10911688].
48 Towner E, Dowswell T, Simpson G, Jarvis S. Health promotion in childhood and young adolescence for the prevention of unintentional injuries. Health Promotion Effectiveness Reviews 1996;1–169.
49 Whitlock EP, Polen MR, Green CA, Orleans T, Klein J. Behavioral counseling interventions in primary care to reduce risky/harmful alcohol use by adults: a summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2004;140(7):557-568. [pmid: 15068985].
50 Foxcroft DR, Ireland D, Lowe G, Breen R. Primary prevention for alcohol misuse in young people. Cochrane Database of Systematic Reviews 2005.
51 Dinh-Zarr T, Goss C, Heitman E, Roberts I, DiGuiseppi C. Interventions for preventing injuries in problem drinkers. Cochrane Database of Systematic Reviews 2004.
52 Harris R, Atkins D, Berg AO, Best D, Eden KB, Feightner JW et al. US Preventive Services Task Force Procedure Manual. Rockville, MD: Agency for Healthcare Research and Quality, 2001.
53 Guyer B, Gallagher SS, Chang BH, Azzara CV, Cupples LA, Colton T. Prevention of childhood injuries: evaluation of the Statewide Childhood Injury Prevention Program (SCIPP). Am J Public Health. 1989;79(11):1521-1527. [pmid: 2817165].
54 Bass JL, Mehta KA, Ostrovsky M, Halperin SF. Educating parents about injury prevention. Pediatr Clin North Am 1985. Feb. 1985;32(1):233-242.
55 Screening and behavioral counseling interventions in primary care to reduce alcohol misuse: recommendation statement. Ann Intern Med 2004; 140(7):554–556.
56 Reisinger KS, Williams AF, Wells JK, John CE, Roberts TR, Podgainy HJ. Effect of pediatricians' counseling on infant restraint use. Pediatrics. 1981;67(2):201-206. [pmid: 7243445].
57 Scherz RG. Restraint systems for the prevention of injury to children in automobile accidents. Am J Public Health. 1976;66(5):451-456. [pmid: 1275118].
58 Kelly B, Sein C, McCarthy PL. Safety education in a pediatric primary care setting. Pediatrics. 1987;79(5):818-824. [pmid: 3554131].
59 Liberato CP, Eriacho B, Schmiesing J, Krump M. SafeSmart Safety Seat Intervention Project: A successful program for the medically-indigent. Patient Educ Couns. 1989;13:161-170.
60 Serwint JR, Wilson ME, Vogelhut JW, Repke JT, Seidel HM. A randomized controlled trial of prenatal pediatric visits for urban, low-income families. Pediatrics. 1996;98(6):1069-1075. [pmid: 8951255].
61 Alvarez J, Jason LA. The effectiveness of legislation, education, and loaners for child safety in automobiles. Journal of Community Psychology. 1993;21(4):280-284.
62 Christophersen ER, Sullivan MA. Increasing the protection of newborn infants in cars. Pediatrics. 1982;70(1):21-25. [pmid: 7088627].
63 Lindqvist KS. Does the use of child safety seats increase as a result of loan schemes?. Accid Anal Prev. 1993;25(4):421-429. [pmid: 8357455].
64 Reisinger KS, Williams AF. Evaluation of programs designed to increase the protection of infants in cars. Pediatrics. 1978;62(3):280-287. [pmid: 704196].
65 Tietge NS, Bender SJ, Scutchfield FD. Influence of teaching techniques on infant car seat use. Patient Educ Couns. 1987;9(2):167-175. [pmid: 10282837].
66 Goodson JG, Buller C, Goodson WH, III. Prenatal child safety education. Obstet Gynecol. 1985;65(3):312-315. [pmid: 3974957].
67 Barone V. An Analysis of well child parenting classes; The Extent of Parent Compliance with Health Care Recommendations to Decrease Potential Injury of Their Toddlers. University of Kansas, 1988.
68 Gittelman MA, Pomerantz WJ, Laurence S. An emergency department intervention to increase booster seat use for lower socioeconomic families. Acad Emerg Med. 2006;13(4):396-400. [pmid: 16531596].
69 Macknin ML, Gustafson C, Gassman J, Barich D. Office education by pediatricians to increase seat belt use. Am J Dis Child. 1987;141(12):1305-1307. [pmid: 3687873].
70 Stevens MM, Olson AL, Gaffney CA, Tosteson TD, Mott LA, Starr P. A pediatric, practice-based, randomized trial of drinking and smoking prevention and bicycle helmet, gun, and seatbelt safety promotion. Pediatrics. 2002;109(3):490-497. [pmid: 11875146].
71 Hempel RJ. Intervention to increase seat belt use at a primary care center. The Journal of the American Board of Family Practice / American Board of Family Practice. 1992;5(5):483-487. [pmid: 1414449].
72 Williams AF. Comment on occupant and licensing interventions. American Journal of Preventive Medicine. 1999;16(1 Suppl):6-8. [pmid: 9921380].
73 Zaza S, Harris KW, Young-Curtis PV, Finley EP, Shults RA, Elder RW, et al. Motor-vehicle occupant injury: strategies for increasing use of child safety seats, increasing use of safety belts, and reducing alcohol-impaired driving: a report on recommendations of the Task Force on Community Preventive Services. Morbidity & Mortality Weekly Report. 2001;50:1-20. [pmid: 11215787].
74 Ehiri J, Ejere H, Magnussen L, Emusu D, King W, Osberg J. Interventions for promoting booster seat use in four to eight year olds treaveling in motor vehicles. The Cochrane Database of Systematic Reviews 2006.
75 Gruen RL, Pearson SD, Brennan TA. Physician-citizens—public roles and professional obligations. JAMA. 2004;291(1):94-98. [pmid: 14709581].
76 Friedlaender E, Winston F. Evidence based advocacy. Inj Prev. 2004;10(6):324-326. [pmid: 15583249].
77 Curry SJ, Ludman EJ, Grothaus LC, Donovan D, Kim E. A randomized trial of a brief primary-care-based intervention for reducing at-risk drinking practices. Health Psychol. 2003;22(2):156-165. [pmid: 12683736].
78 Fleming MF, Barry KL, Manwell LB, Johnson K, London R. Brief physician advice for problem alcohol drinkers. A randomized controlled trial in community-based primary care practices. JAMA. 1997;277(13):1039-1045. [pmid: 9091691].
79 Grossberg PM, Brown DD, Fleming MF. Brief physician advice for high-risk drinking among young adults. Annals of Family Medicine. 2004;2(5):474-480. [pmid: 15506584].
80 Bingham CR, Shope JT. Adolescent developmental antecedents of risky driving among young adults. J Stud Alcohol. 2004;65(1):84-94. [pmid: 15000507].
81 Simpson EM, Moll EK, Kassam-Adams N, Miller GJ, Winston FK. Barriers to booster seat use and strategies to increase their use. Pediatrics. 2002;110(4):729-36. [pmid: 12359786].
82 NHTSA Dictionary of Child Safety Seat Terms. http://nhtsa.gov. National Highway Traffic Safety Administration. 2006.
83 Definition of Blood Alcohol Concentration. http://www.thefreedictionary.com 2006.
84 U.S. Department of Health and Human Services. Injury and Violence Prevention. Health People 2010. Washington, D.C: Government Printing Office, 2000.