# Methods

## Terminology

Terms used in this report are defined in Table 4.

Table 4 Definitions ^82,^ ^83^

[underlined: Alcohol-related motor vehicle crash]: At least one driver or non-occupant (such as a pedestrian or pedal cyclist) involved in the crash is determined to have had a blood alcohol concentration of 0.01 gram per deciliter (g/dL) or higher.
[underlined: Blood alcohol concentration (BAC):] The concentration of alcohol in the blood expressed as the weight of alcohol in a fixed volume of blood and used as a measure of the degree of intoxication in an individual. The concentration depends on body weight, the quantity and rate of alcohol ingestion, and the rates of alcohol absorption and metabolism. Also called blood alcohol level.
[underlined: Belt-positioning booster seat (BPB):] A platform that raises the child (provides a taller sitting height) so adult lap and shoulder belts fit better; some have high backs as well. Never use with a lap belt only across the child.
[underlined: Belt-shortening clip or heavy duty locking clip:] A heavy duty locking clip intended for use to shorten lap belts which have emergency locking retractors for use with a child restraint. Not to be confused with a standard locking clip. Heavy duty locking clips can only be obtained through a vehicle manufacturer.
[underlined: Booster seats:] Are intended to be used as a transition to lap and should belts by older children who have outgrown convertible seats (over 40 lbs). They are available in high backs, for use in vehicles with low seat backs or no head restraints, and no-back; booster bases only.
[underlined: Car seat:] Common term for a specially designed device that secures a child in a motor vehicle, meets federal safety standards, and increases child safety in a crash.
[underlined: Child safety seat/child restraint (CSS):] A crash tested device that is specially designed to provide infant/child crash protection. A general term for all sorts of devices including those that are vests or car beds rather than seats.
[underlined: Convertible child safety seats/restraints:] A child restraint that can be used in more than one mode; usually rear-facing for infants and forward-facing for toddlers.
[underlined: Driver]: A driver is an occupant who is in actual physical control of a transport vehicle or, for an out-of-control vehicle, an occupant who was in control until control was lost.
[underlined: Fatality Analysis Reporting System (FARS):] is a census of fatal crashes within the 50 states, the District of Columbia, and Puerto Rico (although Puerto Rico is not included in US totals). To be included in FARS, a crash must involve a motor vehicle traveling on a traffic way customarily open to the public, and must result in the death of an occupant of a vehicle or a non-motorist within 30 days of the crash. Data are obtained from multiple sources of existing state documents including police accident reports, death certificates, and hospital medical reports.
[underlined: Forward-facing child restraint:] A restraint that is intended for use only in the forward-facing position for a child at least age one and at least 20 pounds up to 40 pounds.
[underlined: General Estimates System (GES):] is a nationally representative probability-based sample of police-reported crashes, from 60 locations across the country, from which estimates of National totals for injury and property-damage-only crashes are derived. To be eligible for the GES sample, a police accident report (PAR) must be completed for the crash, and the crash must involve at least one motor vehicle traveling on a traffic way and must result in a property damage, injury, or death
[underlined: Infant-only restraint]: A restraint designed for us only by a baby (usually weighing less than 17–22 pounds) in a semi-reclined, rear-facing position.
[underlined: Integral/integrated child seat:] A child-sized, forward facing restraint or belt-positioning booster build into a vehicle seat. Some have a full harness and hold children over 20 pounds; others are belt-positioning boosters for use with the adult lap and should belts.
[underlined: Injury]: An injury is bodily harm to a person.
[underlined: Lap belt:] A safety belt anchored at two points, for use across the occupant's things/hips.
[underlined: Lap/shoulder belts:] A safety belt that is anchored at three points and restrains the occupant at the hips and across the shoulder; also called a 'combination belt".
[underlined: Motor vehicle]: A motor vehicle is any motorized (mechanically or electrically powered) road vehicle not operated on rails, including motorcycles, buses, utility vehicles, automobiles, vans, and trucks.
[underlined: National Highway Traffic Safety Administration (NHTSA):] The federal agency that sets performance requirements for motor vehicles and items of motor vehicle equipment such as child restraints.
[underlined: Occupant]: An occupant is any person who is part of a transport vehicle.
[underlined: Passenger]: A passenger is any occupant of a road vehicle other than its driver. Alcohol-related motor vehicle crash - At least one driver or non-occupant (such as a pedestrian or pedal cyclist) involved in the crash is determined to have had a blood alcohol concentration of 0.01 gram per deciliter (g/dL) or higher.
[underlined: Rear-facing infant seat]: Type of child restraint system that is specifically meant for use by children from birth up to approximately 20 pounds used in the rear-facing mode only.
Seat belt positioning devices: these are products marketed and sold to adjust the vehicle seat belt to fit a child. There are no federal safety standards for these products. NHTSA recommends the use of child safety seats and booster seats instead of these products.

## Key Questions and Analytic Framework

Using the USPSTF's methods, ^44^ we developed an analytic framework (Figure 3) and four key questions (KQs) to guide our literature search. KQ1 examined direct evidence for behavioral counseling (BC) interventions to increase the use of age- and weight-appropriate restraints, or to reduce driving/riding with drivers under the influence of alcohol, to decrease morbidity or mortality from motor vehicle occupant injuries. KQ2 and KQ3 addressed the impact of such behavioral counseling interventions on increasing the appropriate use of safety restraints or reducing the incidence of riding or driving with drivers who are under the influence of alcohol. KQ 4 concerned possible harms of BC interventions. This report did not examine the evidence about the efficacy of health risk reduction for MVOI-related safety behaviors since the USPSTF previously judged this as adequately established in 1996.

Figure 3. Analytic framework and key questions

Key Questions: Behavioral counseling interventions to prevent motor vehicle occupant injuries

KQ1. Do primary care behavioral counseling interventions for children, adolescents, and adults to increase the correct use of age - and weight - appropriate restraints or reduce driving/riding with drivers under the influence of alcohol reduce morbidity and/or mortality from motor vehicle occupant injuries?

a) What are the essential elements of efficacious interventions?
b) Are there other positive outcomes from behavioral counseling interventions?

KQ2. Do primary care behavioral counseling interventions for children, adolescents, and adults lead to increased correct use of age- and weight - appropriate restraints?

a) What are the essential elements of efficacious interventions?
b) How long do those counseled continue correct use of age- and weight- appropriate restraints after behavioral counseling intervention?
c) Are there other positive outcomes from counseling to correctly use age- and weight - appropriate restraints?

KQ3. Do primary care behavioral counseling interventions for children, adolescents, and adults reduce driving/riding with drivers under the influence of alcohol?

a) What are the essential elements of efficacious interventions?
b) How long do those counseled continue to reduce driving/riding with drivers under the influence of alcohol after behavioral counseling interventions?
c) Are there other positive outcomes from counseling to reduce driving/riding with drivers under the influence of alcohol?

KQ4. What are the adverse effects of counseling children, adolescents, and adults to correctly use age- and weight - appropriate restraints and reduce driving/riding with drivers under the influence of alcohol?

## Literature Search Strategy

We developed literature search strategies and terms for each KQ (Appendix A, Table 1) and conducted five separate literature searches (Search 1 was for KQ 1 and 2 safety restraints; Search 2 was for KQ 1 and 3 riding with alcohol impaired drivers, Search 3 was for KQs 1 and 3 alcohol use and driving, Search 4 was for KQ 4 harms of counseling for restraints and riding/driving with alcohol impaired drivers, and Search 5 was a cost search). For KQ 1–3 we searched Medline (ML), Cochrane Central Registry of Controlled Trials (CCRCT), Cochrane Database of Systematic Reviews (CDSR), PsycINFO (PI), CINAHL (CN) and Traffic Research Information Service (TRIS) from 1992 to July 2005. For KQ 4, harms of counseling, we searched ML and TRIS from 1996 to September 2005. Even though there was not a key questions related to Cost, we search the NHS Economic Evaluation Database through July 2005 for any articles related to this topic. Literature searches were extensively supplemented with outside source material from experts in the field and from examining the bibliographies of other relevant systematic reviews. ^45^ – ^51^

## Article Review and Data Abstraction

While we conducted five searches to cover the separate focus of each KQ, we reviewed all abstracts for potential inclusion for any of the KQs, utilizing the inclusion/exclusion criteria described in Appendix A, Figure 2. To be included, a study was required to evaluate a behavioral counseling intervention that targeted one of the behaviors specified in our analytic framework and report one of the following outcomes: use or correct use of age- and weight- appropriate restraints, alcohol-impaired driving, riding with an alcohol-impaired driver, morbidity or mortality to occupants from motor vehicle accidents, or harms from counseling. Any intervention that included behavioral counseling among its components was considered for inclusion in the review as were the following study designs: RCTs, CCTs, and comparative observational research designs. To be within the USPSTF's scope, interventions needed to be feasible for, or conducted in, a primary care setting or available for primary care referral. Our criteria for deciding if the intervention was primary care feasible included four domains: 1) how the participant was identified; 2) who delivered the intervention; 3) how the intervention was delivered; and 4) where the intervention was delivered. Appendix B contains a more detailed description of these domains. In order for an intervention to be feasible for primary care referral, we required that it be conducted in a healthcare setting or be widely available in the community at a national level (such as a car-seat-fitting station within a hospital). We excluded studies that enrolled selected populations (e.g., injured or intoxicated patients recruited from an emergency department) who are not representative of patients normally seen in primary care.

Figure 2. Abstract and Article Review Process for Motor Vehicle Occupant Injury Prevention

We reviewed a total of 1289 abstracts and 155 complete articles for all KQs. No articles that met our inclusion criteria for KQs 1–3 were related to driving after drinking or riding with alcohol-impaired drivers. Similarly, we found no relevant articles for KQ 4 concerning harms of behavioral counseling or costs. Listings of excluded articles are in Appendix C. Two investigators rated the quality of all included articles and articles excluded for quality reasons, using the USPSTF's study-design specific criteria (Appendix D). ^44,^ ^52^

There are seventeen studies included in this review: seven from the 1996 USPSTF review, six from other systematic reviews (Appendix E) or outside sources, and four from searches that were conducted for this review. The majority of the trials were published during the 1980's (Table 5). One primary reviewer abstracted relevant information into standardized evidence tables for each included article (Appendix F). A second reviewer checked the abstraction process.

Table 5 Year of publication of articles included in review

< 1980 | 1980-1989 | 1990-1999 | ≥2000
Reisinger, 1978 ^64^ | Barone, 1988 ^67^ | Alvarez, 1993 ^61^ | Gittelman, 2006 ^68^
Scherz, 1976 ^57^ | Christophersen, 1982 ^62^ | Hempel, 1992 ^71^ | Stevens, 2002 ^70^
| Goodson, 1985 ^66^ | Lindqvist, 1993 ^63^
| Guyer, 1989 ^53^ | Serwint, 1996 ^60^
| Kelly, 1987 ^58^
| Liberato, 1989 ^59^
| Macknin, 1987 ^69^
| Reisinger, 1981 ^56^
| Tietge, 1987 ^65^

## Literature Synthesis

We were unable to conduct quantitative synthesis for any key question due to heterogeneity of intervention methods, populations addressed, and settings. Instead, we qualitatively synthesized our results within categories focusing first on the age of the population for which MVOI safety behaviors were addressed, and second on the setting in which the population was identified and in which the intervention was delivered. These qualitative summaries are reflected in the results text and corresponding summary tables. For interventions targeting child safety seat use, results were also stratified by whether or not the program included a demonstration of correct child safety seat use or increased access through a free or discounted distribution program.

## USPSTF Involvement

The authors worked with five USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and resolve issues around scope, intervention settings, and how to integrate the literature from the 1996 review. Research was funded by the Agency for Healthcare Research and Quality (AHRQ) under a contract to support the work of the USPSTF. AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in external review of the draft evidence synthesis.