# References

1 Thom T, Haase N, Rosamond W, et al. Heart Disease and Stroke Statistics—2006 Update: A Report From the American Heart Association Statistics Committee and Stroke Statistics Subcommittee. Circulation %R 101161/CIRCULATIONAHA105171600. 2006;113(6):e85-151.
2 National Center for Health Statistics. Health, United States, 2004: With chartbook on trends in the health of Americans. Hyattsville, Maryland; 2004.
3 Guide to Clinical Preventive Services, 2nd Edition: U.S. Preventive Services Task Force; 1996.
4 Huber TS, Durance PW, Kazmers A, Jacobs LA. Effect of the Asymptomatic Carotid Atherosclerosis Study on carotid endarterectomy in Veterans Affairs medical centers. Arch Surg. 1997;132(10):1134-9. [pmid: 9336515].
5 Morasch MD, Parker MA, Feinglass J, Manheim LM, Pearce WH. Carotid endarterectomy: characterization of recent increases in procedure rates. J Vasc Surg. 2000;31(5):901-9. [pmid: 10805880].
6 Tu JV, Hannan EL, Anderson GM, et al. The fall and rise of carotid endarterectomy in the United States and Canada. N Engl J Med. 1998;339(20):1441-7. [pmid: 9811920].
7 Halm EA, Chassin MR, Tuhrim S, et al. Revisiting the appropriateness of carotid endarterectomy. Stroke. 2003;34(6):1464-71. [pmid: 12738896].
8 Colgan MP, Strode GR, Sommer JD, Gibbs JL, Sumner DS. Prevalence of asymptomatic carotid disease: results of duplex scanning in 348 unselected volunteers. J Vasc Surg. 1988;8(6):674-8. [pmid: 3057243].
9 Fine-Edelstein JS, Wolf PA, O'Leary DH, et al. Precursors of extracranial carotid atherosclerosis in the Framingham Study. Neurology. 1994;44(6):1046-50. [pmid: 8208397].
10 Longstreth WT Jr, Shemanski L, Lefkowitz D, O'Leary DH, Polak JF, Wolfson SK Jr. Asymptomatic internal carotid artery stenosis defined by ultrasound and the risk of subsequent stroke in the elderly. The Cardiovascular Health Study. Stroke. 1998;29(11):2371-6. [pmid: 9804651].
11 Meissner I, Whisnant JP, Khandheria BK, et al. Prevalence of potential risk factors for stroke assessed by transesophageal echocardiography and carotid ultrasonography: the SPARC study. Stroke Prevention: Assessment of Risk in a Community. Mayo Clin Proc. 1999;74(9):862-9. [pmid: 10488786].
12 Pujia A, Rubba P, Spencer MP. Prevalence of extracranial carotid artery disease detectable by echo-Doppler in an elderly population. Stroke. 1992;23(6):818-22. [pmid: 1595098].
13 Du X, McNamee R, Cruickshank K. Stroke risk from multiple risk factors combined with hypertension: a primary care based case-control study in a defined population of northwest England. Ann Epidemiol. 2000;10(6):380-8. [pmid: 10964004].
14 Hadjiev DI, Mineva PP, Vukov MI. Multiple modifiable risk factors for first ischemic stroke: a population-based epidemiological study. European Journal of Neurology. 2003;10(5):577-82. [pmid: 12940842].
15 Bogousslavsky J, Van Melle G, Regli F. The Lausanne Stroke Registry: analysis of 1,000 consecutive patients with first stroke. Stroke. 1988;19(9):1083-92. [pmid: 3413804].
16 Ergin A, Muntner P, Sherwin R, He J. Secular trends in cardiovascular disease mortality, incidence, and case fatality rates in adults in the United States. Am J Med. 2004;117(4):219-27. [pmid: 15308430].
17 Petty GW, Brown RD Jr, Whisnant JP, Sicks JD, O'Fallon WM, Wiebers DO. Ischemic stroke subtypes: a population-based study of incidence and risk factors. Stroke. 1999;30(12):2513-6. [pmid: 10582970].
18 Rodriguez BL, D'Agostino R, Abbott RD, et al. Risk of hospitalized stroke in men enrolled in the Honolulu Heart Program and the Framingham Study: A comparison of incidence and risk factor effects. Stroke. 2002;33(1):230-6. [pmid: 11779915].
19 Rosamond WD, Folsom AR, Chambless LE, et al. Stroke incidence and survival among middle-aged adults: 9-year follow-up of the Atherosclerosis Risk in Communities (ARIC) cohort. Stroke. 1999;30(4):736-43. [pmid: 10187871].
20 Schneider AT, Kissela B, Woo D, et al. Ischemic stroke subtypes: a population-based study of incidence rates among blacks and whites. Stroke. 2004;35(7):1552-6. [pmid: 15155974].
21 Barnett HJ, Gunton RW, Eliasziw M, et al. Causes and severity of ischemic stroke in patients with internal carotid artery stenosis. Jama. 2000;283(11):1429-36. [pmid: 10732932].
22 Mannami T, Baba S, Ogata J. Strong and significant relationships between aggregation of major coronary risk factors and the acceleration of carotid atherosclerosis in the general population of a Japanese city: the Suita Study. Arch Intern Med. 2000;160(15):2297-303. [pmid: 10927726].
23 Mathiesen EB, Joakimsen O, Bonaa KH. Prevalence of and risk factors associated with carotid artery stenosis: the Tromso Study. Cerebrovasc Dis. 2001;12(1):44-51. [pmid: 11435679].
24 O'Leary DH, Polak JF, Kronmal RA, Kittner SJ, et al. Distribution and correlates of sonographically detected carotid artery disease in the cardiovascular health study. Stroke. 1992;23:1752-60. [pmid: 1448826].
25 Rockman CB, Jacobowitz GR, Gagne PJ, et al. Focused screening for occult carotid artery disease: patients with known heart disease are at high risk. J Vasc Surg. 2004;39(1):44-51. [pmid: 14718811].
26 Tell GS, Polak JF, Ward BJ, Kittner SJ, Savage PJ, Robbins J. Relation of smoking with carotid artery wall thickness and stenosis in older adults. The Cardiovascular Health Study. The Cardiovascular Health Study (CHS) Collaborative Research Group. Circulation. 1994;90(6):2905-8. [pmid: 7994837].
27 Wilson PW, Hoeg JM, D'Agostino RB, et al. Cumulative effects of high cholesterol levels, high blood pressure, and cigarette smoking on carotid stenosis. N Engl J Med. 1997;337(8):516-22. [pmid: 9262494].
28 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
29 Nederkoorn PJ, van der Graaf Y, Hunink MG. Duplex ultrasound and magnetic resonance angiography compared with digital subtraction angiography in carotid artery stenosis: a systematic review. Stroke. 2003;34(5):1324-32. [pmid: 12690221].
30 Jahromi AS, Cina CS, Liu Y, Clase CM. Sensitivity and specificity of color duplex ultrasound measurement in the estimation of internal carotid artery stenosis: a systematic review and meta-analysis. J Vasc Surg. 2005;41(6):962-72. [pmid: 15944595].
31 Koelemay MJ, Nederkoorn PJ, Reitsma JB, Majoie CB. Systematic review of computed tomographic angiography for assessment of carotid artery disease. Stroke. 2004;35(10):2306-12. [pmid: 15345798].
32 Clagett GP, Youkey JR, Brigham RA, et al. Asymptomatic cervical bruit and abnormal ocular pneumoplethysmography: a prospective study comparing two approaches to management. Surgery. 1984;96(5):823-30. [pmid: 6387988].
33 Results of a randomized controlled trial of carotid endarterectomy for asymptomatic carotid stenosis. Mayo Asymptomatic Carotid Endarterectomy Study Group. Mayo Clin Proc. 1992;67(6):513–8.
34 Hobson RW 2nd, Weiss DG, Fields WS, et al. Efficacy of carotid endarterectomy for asymptomatic carotid stenosis. The Veterans Affairs Cooperative Study Group. N Engl J Med. 1993;328(4):221-7. [pmid: 8418401].
35 Endarterectomy for asymptomatic carotid artery stenosis. Executive Committee for the Asymptomatic Carotid Atherosclerosis Study. Jama 1995;273(18):1421–8.
36 Halliday A, Mansfield A, Marro J, et al. Prevention of disabling and fatal strokes by successful carotid endarterectomy in patients without recent neurological symptoms: randomised controlled trial. Lancet. 2004;363(9420):1491-502. [pmid: 15135594].
37 Benavente O, Moher D, Pham B. Carotid endarterectomy for asymptomatic carotid stenosis: a meta-analysis. Bmj. 1998;317(7171):1477-80. [pmid: 9831572]. [pmcid: 28726].
38 Chambers BR, You RX, Donnan GA. Carotid endarterectomy for asymptomatic carotid stenosis. Cochrane Database Syst Rev 2000(2):CD001923.
39 Baker WH, Howard VJ, Howard G, Toole JF. Effect of contralateral occlusion on long-term efficacy of endarterectomy in the asymptomatic carotid atherosclerosis study (ACAS). ACAS Investigators. Stroke. 2000;31(10):2330-4. [pmid: 11022059].
40 Role of carotid endarterectomy in asymptomatic carotid stenosis. A Veterans Administration Cooperative Study. Stroke 1986;17(3):534–9.
41 Grzyska U, Freitag J, Zeumer H. Selective cerebral intraarterial DSA. Complication rate and control of risk factors. Neuroradiology. 1990;32(4):296-9. [pmid: 2234388].
42 Heiserman JE, Dean BL, Hodak JA, et al. Neurologic complications of cerebral angiography. AJNR Am J Neuroradiol. 1994;15(8):1401-7. discussion 8–11. [pmid: 7985557].
43 Willinsky RA, Taylor SM, TerBrugge K, Farb RI, Tomlinson G, Montanera W. Neurologic complications of cerebral angiography: prospective analysis of 2,899 procedures and review of the literature. Radiology. 2003;227(2):522-8. [pmid: 12637677].
44 Kresowik TF, Bratzler DW, Kresowik RA, et al. Multistate improvement in process and outcomes of carotid endarterectomy. J Vasc Surg. 2004;39(2):372-80. [pmid: 14743139].
45 Horner RD, Oddone EZ, Stechuchak KM, et al. Racial variations in postoperative outcomes of carotid endarterectomy: evidence from the Veterans Affairs National Surgical Quality Improvement Program. Med Care. 2002;40(1 Suppl):I35-43. [pmid: 11789630].
46 Samsa G, Oddone EZ, Horner R, Daley J, Henderson W, Matchar DB. To what extent should quality of care decisions be based on health outcomes data? Application to carotid endarterectomy. Stroke. 2002;33(12):2944-9. [pmid: 12468795].
47 Bratzler DW, Oehlert WH, Murray CK, Bumpus LJ, Moore LL, Piatt DS. Carotid endarterectomy in Oklahoma Medicare beneficiaries: patient characteristics and outcomes. J Okla State Med Assoc. 1996;89(12):423-9. [pmid: 8997882].
48 Cebul RD, Snow RJ, Pine R, Hertzer NR, Norris DG. Indications, outcomes, and provider volumes for carotid endarterectomy. Jama. 1998;279(16):1282-7. [pmid: 9565009].
49 Halm EA, Tuhrim S, Wang JJ, Rojas M, Hannan EL, Chassin MR. Has evidence changed practice?: appropriateness of carotid endarterectomy after the clinical trials. Neurology. 2007;68(3):187-94. [pmid: 17224571].
50 Karp HR, Flanders WD, Shipp CC, Taylor B, Martin D. Carotid endarterectomy among Medicare beneficiaries: a statewide evaluation of appropriateness and outcome. Stroke. 1998;29(1):46-52. [pmid: 9445327].
51 Kresowik TF, Bratzler D, Karp HR, et al. Multistate utilization, processes, and outcomes of carotid endarterectomy. J Vasc Surg. 2001;33(2):227-34. discussion 34–5. [pmid: 11174772].
52 Kresowik TF, Hemann RA, Grund SL, et al. Improving the outcomes of carotid endarterectomy: results of a statewide quality improvement project. J Vasc Surg. 2000;31(5):918-26. [pmid: 10805882].
53 Halm EA, Hannan EL, Rojas M, et al. Clinical and operative predictors of outcomes of carotid endarterectomy. J Vasc Surg. 2005;42(3):420-8. [pmid: 16171582].
54 Press MJ, Chassin MR, Wang J, Tuhrim S, Halm EA. Predicting medical and surgical complications of carotid endarterectomy: comparing the risk indexes. Arch Intern Med. 2006;166(8):914-20. [pmid: 16636219].
55 Rockman CB, Halm EA, Wang JJ, et al. Primary closure of the carotid artery is associated with poorer outcomes during carotid endarterectomy. J Vasc Surg. 2005;42(5):870-7. [pmid: 16275440].
56 Bond R, Perkasem K, Rothwell PM. Systematic Review of the Risks of Carotid Endarterectomy in Relation to the Clinical Indication for and Timing of Surgery. Stroke - Journal Of The American Heart Association 2003:2290–03.
57 Rothwell PM. ACST: which subgroups will benefit most from carotid endarterectomy?. Lancet. 2004;364(9440):1122-3. author reply 5–6. [pmid: 15451212].
58 Lee TH, Marcantonio ER, Mangione CM, et al. Derivation and prospective validation of a simple index for prediction of cardiac risk of major noncardiac surgery. Circulation. 1999;100(10):1043-9. [pmid: 10477528].
59 Finsterer J, Stollberger C. ACST: which subgroups will benefit most from carotid endarterectomy?. Lancet. 2004;364(9440):1124. author reply 5–6. [pmid: 15451214].
60 Kietselaer BL, Hofstra L, Narula J. ACST: which subgroups will benefit most from carotid endarterectomy?. Lancet. 2004;364(9440):1124-5. author reply 5–6. [pmid: 15451215].
61 Kumar S, Sinha B. ACST: which subgroups will benefit most from carotid endarterectomy?. Lancet. 2004;364(9440):1125. author reply -6. [pmid: 15451217].
62 Masuhr F, Busch M. ACST: which subgroups will benefit most from carotid endarterectomy?. Lancet. 2004;364(9440):1123-4. author reply 5–6. [pmid: 15451213].
63 Coward LJ, Featherstone RL, Brown MM. Safety and efficacy of endovascular treatment of carotid artery stenosis compared with carotid endarterectomy: a Cochrane systematic review of the randomized evidence. Stroke. 2005;36(4):905-11. [pmid: 15746454].
64 Yadav JS, Wholey MH, Kuntz RE, et al. Protected carotid-artery stenting versus endarterectomy in high-risk patients. N Engl J Med. 2004;351(15):1493-501. [pmid: 15470212].