# Research Gaps

High quality studies of the true prevalence (rather than ultrasound-based prevalence) of clinically important CAS in usual primary care populations are needed. Other research gaps include: 1) evidence for a validated, reliable risk stratification tool that would allow us to distinguish those people who might benefit from screening from those who would more likely be harmed; 2) evidence on improved screening strategies that do not generate large numbers of false positive tests and unnecessary harms; and 3) further studies on confirmatory strategies that do not lead to additional harms.