# Emerging Issue - Stenting for Carotic Artery Stenosis

The use of carotid artery angioplasty with stenting for CAS has increased in recent years. This technology has emerged as a potential alternative to CEA for patients who are not candidates for CEA because of high-risk comorbidities.

A Cochrane Systematic Review of 5 RCTs of stenting versus CEA for symptomatic and asymptomatic patients at high risk for complications from CEA found no difference in 30-day or 1-year outcomes between treatment groups.^63^ No study has randomized asymptomatic patients similar to those in the ACAS or ACST trials to stenting versus CEA, and no trial has reported results beyond one year. The largest study that reported the most positive results showed a non-statistically significant trend toward a reduction in perioperative stroke, death, and non-fatal MI.^64^ This study, however, was terminated early because of slow recruitment. Thus, we cannot determine whether there are any differences in the benefits of stenting compared with CEA.