# Results

## Summary of Results

We found no direct evidence of the benefit of screening with ultrasound for CAS in asymptomatic adults (KQ1). Two systematic reviews were found on the accuracy of ultrasound screening (KQ2); the sensitivity is approximately 94% and the specificity is approximately 92% for CAS of 60%–99%. Three fair or good quality RCTs were found and reported that in selected patients with selected surgeons treatment with CEA for asymptomatic CAS could lead to an approximately 5% absolute reduction in strokes over 5 years (KQ3).

For the systematic review for KQ4, the initial literature search returned 397 titles. The titles, abstracts and full articles were reviewed by three reviewers. 232 studies were excluded after review of returned titles by three reviewers. Most of the studies were excluded at the title stage for the following reasons: not on CEA, not multi-site, or only included outcomes for symptomatic subjects. 134 studies were excluded at the abstract stage (Figure 2). The majority of studies were excluded for including only symptomatic subjects, not multi-site, no relevant outcomes, or small sample size. Three full articles were identified through expert consultation or from reviewing the reference lists of major review articles. 20 full articles were excluded because of incorrect study type, not multi-site, only included symptomatic subjects, or did not report relevant outcomes. Fourteen articles were ultimately included for key question 4 on the harms of CEA. In addition, three good or fair quality RCTs identified for KQ3 also provided evidence on harms under trial conditions.

Figure 2. Literature search results for key question 4 on the harms of carotid endarterectomy

CEA = carotid endarterectomy

The harms of CEA for asymptomatic CAS, reported in most studies as thirty-day stroke and death rates, vary from 2.7% to 4.7% in the RCTs; higher rates have been reported in observational studies (up to 6.7%). Details of the results of the literature search and synthesis are below under the corresponding key question subheading.

## Key Question 1. Is there direct evidence that screening adults with ultrasound for asymptomatic CAS reduces fatal and/or nonfatal stroke?

We found no studies that addressed this question.

## Key Question 2. What is the accuracy and reliability of ultrasound to detect clinically important CAS?

We found two meta-analyses on the accuracy of ultrasound to detect clinically important stenosis. A recent meta-analysis included studies published from 1993 through 2001, and estimated the accuracy of carotid duplex ultrasound using digital subtraction angiography as the reference standard.^29^ Carotid duplex ultrasound had an estimated sensitivity of 86% (95% CI, 84% to 89%) and a specificity of 87% (95% CI, 84% to 90%) for detecting CAS of 70%–99%.^29^ A second meta-analysis of carotid duplex ultrasound found similar sensitivity and specificity for carotid duplex ultrasound to detect 70% or greater stenosis, 90% (95% CI, 84–94%) and 94% (95% CI, 88–97%) respectively.^30^ To detect CAS ≥ 50%, the authors suggested a cut-point that had a sensitivity of 98% and a specificity of 88%. Reading from a graph in this paper and using the same cut point as was suggested for detecting ≥ 70% CAS, we estimate that the sensitivity of carotid duplex ultrasound to detect CAS ≥ 60% is about 94%, with a specificity of about 92%.

The reliability of carotid duplex ultrasound is questionable. One meta-analysis noted that the measurement properties used among various ultrasound laboratories varied greatly, to a clinically important degree.^30^

We found one meta-analysis on accuracy of MRA and one meta-analysis on the accuracy of CT in detecting clinically important carotid stenosis. The meta-analysis on the accuracy of MRA reported that MRA has about the same accuracy as ultrasound.^29^ CTA has gained wide acceptance in some centers as a follow up test to ultrasound in confirming CAS. In certain cases, it has been used in place of vascular arteriogram. A recent systematic review found that its accuracy is not greatly different from that of ultrasound and MRA.^31^ Although CTA is safer than angiography as a confirmatory test, it is unlikely to be a useful screening test due to its cost, radiation exposure and injection of intravenous contrast dye. MRA does not use contrast dye or have significant radiation exposure. It is, however, time-consuming and costly and is also not suitable as a screening test at this time. Currently, the most available and acceptable screening test for CAS remains carotid duplex ultrasound.

The prevalence of CAS has been studied in several population-based cohort studies. These prevalence estimates are based on a positive test result on a screening carotid ultrasound, which, as noted above, has less than perfect accuracy. The Cardiovascular Health Study (CHS) of 5441 community-dwelling people ages 65 years and older showed a 3.4% observed prevalence for 50–99% CAS and a 0.5% observed prevalence of 70–99% CAS.^10^ In the Framingham Study, the observed prevalence of CAS ≥ 60% was 3.3% among participants 65 years and older.^9^ Meissner and colleagues found an 8% prevalence of 50–99% CAS in a randomly selected cohort of 1475 older adults in Minnesota. Several other smaller population-based cohort studies reported similar results.^8,^ ^11,^ ^12^

These studies used carotid duplex ultrasound, which likely resulted in an overestimate of the prevalence due to the test's high number of false positives in low prevalence groups. For example, a screening test with a sensitivity of 94% and a specificity of 92% used in a population with a true 1% prevalence of CAS 60%–99% would estimate the prevalence to be 8.9%. At a true prevalence of 5%, this test would estimate the prevalence to be 12.3%. This illustrates the number of false positive tests generated when using a screening test in a low-prevalence population.

We estimate that the actual prevalence of CAS 60%–99% in the general primary care population is less than 1%; and about 1% in individuals 65 and older. People with more cardiovascular risk factors or existing atherosclerotic disease may have a higher prevalence. As noted earlier, however, a risk stratification tool to identify people at higher risk for CAS is not available.

Two lines of evidence allow us to estimate the prevalence of CAS 60%–99% to be about 1% in the general population of asymptomatic people over age 65. First, the population-based Cardiovascular Health Study findings for people 65 and older used stroke risk to define the clinical importance of various degrees of CAS.^10^ This study found that 0.5% of the population had a 5-year stroke risk of 5%, corresponding to CAS of 70% or greater. The second line of evidence comes from studies of the prevalence of CAS 60%–99% as measured by duplex ultrasound. Data from the Cardiovascular Health Study, the Framingham Study, and the Minnesota cohort show prevalence of CAS 60%–99% measured by duplex ultrasound was from 3% to 8%.^8^–^12^ Given a sensitivity of ultrasound of 94% and a specificity of 92% for this degree of CAS, the true prevalence of CAS 60%–99% corresponding to these measured values would all be less than 1%. From these 2 lines of evidence, we estimate that the true prevalence of CAS 60%–99% in the general population of asymptomatic people 65 and older to be about 1%.

## Key Question 3. For people with asymptomatic CAS 60%–99%, does intervention with CEA reduce CAS-related morbidity or mortality?

We identified 5 RCTs comparing CEA and medical management for asymptomatic CAS: the Walter Reed Army Medical Center Study (WRAMC) study ^32^, the Mayo Asymptomatic Carotid Endarterectomy Study (MACE) ^33^, the Veterans Affairs Cooperative Study (VACS), ^34^ the Asymptomatic Carotid Atherosclerosis Study (ACAS) ^35^, and the Asymptomatic Carotid Surgery Trial (ACST). ^36^ In addition, we reviewed two systematic reviews (Benavente ^37^ and Cochrane ^38^) of CEA for asymptomatic CAS and one post hoc analysis of ACAS results.^39^ Both the Benavente and Cochrane systematic reviews were published before the ACST trial reported its results, and thus did not include this study. Otherwise, these reviews found the same studies as are reviewed here, with the exception of an unpublished RCT from France included in the Benavente report that we did not include because we could not examine its validity.

The table in Appendix 3 summarizes study characteristics and outcomes. We reviewed two good quality studies (ACAS, ACST) and one fair quality study (VACS). We excluded the WRAMC study because it did not use ultrasound assessment of CAS, had a small number of participants, and used unclear definitions of outcomes. We excluded the MACE study because of its small number of participants, small number of strokes, and the lack of aspirin treatment in the surgical group.

The three fair or good quality studies, VACS, ACAS, and ACST, compared CEA plus medical management to medical management alone in subjects without symptoms attributable to the studied artery (Table 1). Medical management included the standard risk factor management at the time of the trials, including aspirin and some degree of blood pressure and lipid control. In the VACS, 444 men with 50%–99% stenosis confirmed by angiography were randomized and followed for a mean of 47.9 months.^40^ All subjects were male, 88% were white, and the median age was 64.5 years. The participants had a generally high cardiovascular risk; approximately 50% were current cigarette smokers, about 30% had diabetes, and 63% had hypertension. After 4 years of follow-up, the stroke rate was lower in the CEA group than in the medical treatment group, 8.6% versus 12.4%. However, there was also a 4.7% incidence of perioperative stroke or death in the CEA group. When all strokes or perioperative events were considered, there was no difference between CEA and medical management.

Table 1 Evidence Table for Randomized Controlled Trials for Effectiveness of Surgery versus Medical Management for Asymptomatic Carotid Artery Stenosis

Study | Sample Size & Basic Demographics | Mean Follow-up Time | 30-day Perioperative Complic. Rate: | | Five Year Outcomes :* | Quality Rating
VACS^31^ | Total = 444 | 48 months | Stroke or death: | 4.7% | Five-year incidence of any stroke & perioperative death: | Fair
| MM = 233 | | MI: | 1.9% | MM: 44.2%
| CEA = 211 | | | | CEA: 41.2%
| Mean age: 65 years | | | | RR 0.92 (95% CI, 0.69–1.22)
| Male 100%
| White: 86–88%
ACAS^32^ | Total = 1659 | 2.7 years | Stroke or death: | 2.7% | Rate of perioperative stroke or death & subsequent ipsilateral stroke: | Good
| MM = 834 | | MI: | NR% | MM = 11%
| CEA = 825 | | [underlined: Sex:] | | CEA = 5.1%
| Mean age: 67 years | | Women: | 3.6% | RRR = 53% (95% CI, 22–72%)
| Male: 66% | | Men: | 1.7% | ARR = 5.9%
| White: 94–95% | | | | [underlined: Sex:]
| | | | | W: RRR 17% (95% CI, -%96–65%)
| | | | | M: RRR 66% (95% CI, 36–82%)
| | | | | [underlined: Age:]
| | | | | < 68: RRR 0.60 (95% CI, 0.11–0.82)
| | | | | ≥ 68: RRR 0.43 (95% CI, -0.07–0.70)
ACST^33^ | Total = 3,120 | 3.4 years | Stroke or death: | 2.8% | Five-year incidence of any stroke & perioperative death: | Good
| MM = 1,560 | | MI: | 0.6 % | MM = 11.8% (SE 1.00)
| CEA = 1,560 | | [underlined: Sex]: ∞ | | CEA = 6.4% (SE 0.70)
| Mean age = 68 years | | Women: | 3.1% | ARR = 5.4% (95% CI 2.96–7.75)
| Male 66% | | Men: | 2.2% | [underlined: Sex:] §
| White: NR | | [underlined: Age:] | | W: ARR= 4.1% (95% CI 0.74–7.41)
| | | < 65: | 2.4% | M: ARR= 8.2% (95% CI 5.64–10.78)
| | | 65–74: | 2.3% | [underlined: Age]: §
| | | ≥ 75: | 3.3% | < 65: ARR 7.8% (95% CI 4.28–11.31)
| | | | | 65–74: ARR 7.5% (95% CI4.67–10.30)
| | | | | ≥ 75: ARR 3.3%

* Standard errors and 95% confidence intervals are listed here if reported in the studies.

§ Five-year non-perioperative stroke;

VACS = Veterans Affairs Cooperative Study, ACAS = Asymptomatic Carotid Atherosclerosis Study, ACST = Asymptomatic Carotid Surgery Trial, NR=Not reported, MM = medical management group, CEA = carotid endarterectomy group, NR = not reported, MI = myocardial infarction, CI = confidence interval, RR = relative risk, ARR = absolute risk reduction, RRR = relative risk reduction, SE = standard error, W = women, M = men

ACAS screened about 42,000 people and selected 1,662 with angiographically confirmed CAS ≥ 60% for randomization to CEA or medical therapy.^35^ Subjects were 95% white, 66% male, and had a mean age of 67 years. Again, the participants had a high cardiovascular risk; about 20% had had a previous contralateral CEA, over 20% had had a previous contralateral TIA or stroke, 64% had hypertension, 26% smoked cigarettes, and 23% had diabetes. Surgeons with low CEA complication rates were selected for participation in the study.

After 2.7 years follow-up, ACAS authors estimated 5-year outcomes based on Kaplan-Meier curves. The authors estimated that the 5-year rate of ipsilateral stroke and any perioperative stroke or death was lower in the CEA group than in the medical group, 5.1% versus 11.0%. (Relative risk reduction [RRR] 0.53; 95% CI 0.22–0.72) If strokes associated with angiography were included, the difference between groups was 5.6% versus 11.0%, or an absolute difference of 5.4% over 5 years. These rates include a perioperative rate of stroke or death of 2.7% overall (1.7% for men and 3.6% for women). The estimated RRR for men was greater than for women: 0.66 and 0.17, respectively. There was no statistically significant difference between treatment groups in all-cause mortality.

The ACST is the most recent and largest RCT of CEA versus medical treatment for asymptomatic CAS. This international, multicenter trial randomized 3,120 subjects with ≥ 60% CAS and followed them for a mean of 3.4 years.^36^ Both groups received medical management by their primary care providers. Although it is difficult to determine the intensity of medical management, the mean systolic blood pressure at baseline for all subjects was 153 mmHg and mean total cholesterol was 224 mg/dL. Aspirin was widely used. More than 50% of the patients were on antihypertensive medications but the achieved systolic blood pressure was not reported. Lipid lowering agents were used with less frequency at the beginning of the study, and were used by more than 50% of participants during the last 3 years of the study.

In ACST, the degree of CAS was determined by ultrasound. Angiography was not required but was often used for confirmation of CAS during the first few years of the study, and less frequently used in the final years. As in the ACAS study, patients were carefully selected and were generally at high cardiovascular risk. Mean age was 68 years, 66% were male, 65% had hypertension, 20% had diabetes, and 24% had had a previous contralateral CEA. As in ACAS, the ACST surgeons were carefully selected for low complication rates. The perioperative rate of stroke or death was 3.1% overall, but higher for women (3.7%) than for men (2.4%).

After 3.4 years follow-up, the ACST authors estimated 5-year outcomes. They estimated that the CEA group would have a lower 5-year rate of any stroke or perioperative death than the medical group, 6.4% versus 11.8% (difference 5.35%; 95% CI 2.96%–7.75%). About half of the strokes prevented by CEA were disabling. There was no statistically significant difference between groups in all-cause mortality.

Before the ACST was published, 2 reviews of CEA for asymptomatic CAS were reported.^37,^ ^38^ Benavente performed a meta-analysis using data from WRAMC, MACE, VACS, ACAS, and Association Universitaire de Recherche en Chirurgie (AURC, an unpublished trial in France).^37^ Little information is available about the methodology of AURC. Benavente and his colleagues found a rate of all strokes plus perioperative stroke or death of 7.4% and 9.2% for the surgical group and medical group, respectively and an OR of 0.68 (95% CI, 0.51–0.90). These rates included a pooled estimate for perioperative complications of 2.4%.

The Cochrane review published in 2002 combined data from the ACAS and VACS; the combined RR for CEA versus medical management was 0.68 (95% CI, 0.48–0.97) for ipsilateral stroke or perioperative death at five years.^38^ Subjects in the surgical group had statistically significantly lower rates of any stroke or perioperative death at five years, compared to medical management (RR 0.76, 95% CI 0.58–0.99).

There are important limitations of the RCTs on CEA for asymptomatic CAS. The participants in the RCTs were a highly select group of subjects and surgeons, a situation that reduces the findings' generalizability to the primary care setting. In addition, the 30-day perioperative results of the RCTs were reported as a combined outcome that did not include an important complication, acute non-fatal myocardial infarction. Another important limitation of the RCTs on treatment with CEA is that the medical treatment arm in the RCTs was ill-defined, was not kept constant over the course of the study, and was likely not comparable to current standards of optimal medical management.

In summary, the 2 largest and best-conducted RCTs (and meta-analyses including one of those RCTs) have shown a reduction in the important outcome of stroke and perioperative death from CEA as compared with medical treatment for CAS of 60%–99% in selected patients with selected surgeons.

### Is there a population subgroup for which the magnitude of benefits from CEA may be greater than in other subgroups?

Studies reviewed for KQ3 and KQ 4 were examined for demographic and co-morbidity subanalyses. Please see the section after KQ4 results for a detailed discussion.

## Key Question 4. Does treatment for asymptomatic CAS 60%–99% with CEA result in harm?

The potential harms of a program of screening for CAS for the purpose of performing CEA include (1) the harms associated with false positive screening tests (e.g., anxiety, labeling, the harms of any confirmatory work-up, such as angiography, or the harms of unnecessary CEA in people who do not undergo angiography); and (2) the harms of CEA itself (e.g., bleeding, infection, stroke, and death). We found no studies exploring anxiety or labeling among people with falsely positive ultrasound screening tests. We did find evidence concerning the harms of angiography and CEA.

### Harms Associated with Cerebral Angiography

Although cerebral angiography is the “gold standard” for confirming CAS, a small percentage of patients will be harmed by the angiogram procedure itself. In the ACAS study, for example, 1.2% of patients who had an angiogram had a non-fatal stroke. In the VACS study, this was 0.4%.(30, 35) Other prospective studies of cerebral angiogram have found rates of persistent neurological complications of 0.1%–0.5%.^41^–^43^ However, several of these prospective studies found higher rates in subjects with CAS or cardiovascular disease. This may explain the higher rate of angiogram complications in the ACAS study.

Because of the increased risk of stroke, there is disagreement on whether cerebral angiography should be used to confirm a positive ultrasound screening test. There is considerable variation in current practice. Some surgeons do other confirmatory tests, such as MRA or CTA, while others request angiography prior to CEA. Kresowik reported in 2004 a ten-state aggregate preoperative angiogram utilization rate of 64% (for symptomatic and asymptomatic patients combined).^44^ Although MRA and CTA are not as accurate as angiography - and thus may lead to unnecessary CEA in patients with false positive screening tests - they are not associated with complicating strokes.

### Harms Associated with CEA for Asymptomatic CAS

#### Study characteristics

We identified fourteen good or fair quality studies that met our inclusion criteria and evaluated CEA complications in patients with asymptomatic CAS. Detailed study characteristics, quality ratings, and results of the observational studies are displayed in a table in Appendix 4. Thirteen observational studies were secondary analyses of administrative databases: two studies were performed using data on patients attending a Veterans Affairs medical center; ^45,^ ^46^ seven studies used data from patients receiving Medicare benefits;^44,^ ^47^–^52^ and four studies used a similar dataset of patients admitted to six New York hospitals.^7,^ ^53^–^55^ The final study was a systematic review of studies published between 1994 and 2000 on harms of CEA.^56^ The primary perioperative complication measure in the studies was either death/stroke or death/stroke/myocardial infarction within 30 days of surgery. All of the observational studies included patients referred to a hospital or medical center for CEA as a result of CAS. There was little data about the severity of stenosis. The studies included both patients who did and did not have neurological symptoms, but we only reviewed studies that reported complication rates separately for asymptomatic patients. Mean age of patients ranged from 67 to 74 years. Six of the studies collected information on race. In those studies that reported race, the participants were largely white (range 87–95%). Although the subjects in the two Veterans Affairs studies were almost entirely all male subjects, the other studies did include 36–47% female subjects.

The Bratzler study from 1998 used a claims database and medical records from Medicare recipients who received a CEA in 1993 or 1994.^47^ We quality rated this study as good: data for outcomes were collected from two sources - claims data and medical records, correlation between data abstractors was high, and there were standard definitions of outcomes. The fair quality study by Cebul and colleagues used Ohio Medicare claims data on patients who received a CEA between July 1993 and June 1994; this was a predominantly white population and the study used only a subset of all patients receiving CEA during the timeframe.^48^

Two good quality studies on the same database of patients undergoing CEA at Veterans Affairs medical centers had well-defined inclusion criteria and abstraction processes and used methods that likely limited differential outcome measurement, including contacting all patients and families 30 days after surgery.^45,^ ^46^ Two good quality studies by Kresowik and colleagues used Medicare claims databases from ten states - the first for June 1995 to May 1996 and the second for June 1998 to May 1999.^44,^ ^51^ These studies were very large and included medical record data in addition to data in the claims database. Another good quality study by Kresowik and colleagues used similar methods as above but used the Iowa Medicare database.^52^ A fair quality study by Karp and colleagues used Medicare claims data from the state of Georgia; there was limited agreement between the reviewer and the physicians in this study on indications for surgery.^50^

Four studies used the same database of Medicare recipients from 6 New York hospitals who underwent CEA in 1997 or 1998.^7,^ ^53^–^55^ The individual studies used similar methods but had different research questions and consequently excluded cases with missing data using different criteria. While these four studies had some limitations, the overall quality of the studies was rated as good quality for the following reasons: both outpatient and inpatient data were used for outcome measurement, studies used trained independent abstractors, two investigators independently reviewed records of subjects with an outcome, and there was limited exclusions of cases due to missing data.

The 2007 study by Halm and colleagues was performed on a administrative database of Medicare recipients in New York State who received a CEA between January 1998 and June 1999.^49^ Several limitations lead to a fair quality rating including the exclusion of a large number of cases due to missing data. The systematic review by Bond and colleagues included studies that reported 30 day stroke and death rates by indication and excluded studies on combined CEA and coronary artery bypass grafting^56^. This study had several limitations resulting in a fair quality rating including a lack of discussion on the standard assessment of study quality.

### Summary of Study Results

The 30-day perioperative stroke or death rates in asymptomatic subjects in the Medicare and New York City studies ranged from 2.3% to 3.7%. One Veterans Affairs study showed a perioperative stroke or death rate of 1.6%.^45^ The systematic review of 103 studies found an overall stroke and death rate at 30 days of 3.0% in studies published since 1995.^56^

The observational studies reporting perioperative non-fatal MIs showed a rate of approximately 0.7% to 1.1%. ^7,^ ^45,^ ^50^ Patients with more co-morbidities had a rate of non-fatal myocardial infarction up to 3.3%.^7^ The rate of non-fatal perioperative myocardial infarction reported for the surgical group in the RCTs varied: 1.9% in VACS and 0.6% in ACST.^34,^ ^36^ The subjects did not receive routine post-operative electrocardiograms or serum markers of myocardial involvement.

Two Medicare-based studies found variation in perioperative stroke and death among 10 states.^44,^ ^51^ In the first study, the state-wide rates ranged from 2.3% in Indiana to 6.7% in Arkansas.^51^ A follow-up study for the same ten states found similar results as in 2001, with rates ranging from 1.4% in Georgia to 6.0% in Oklahoma.^44^

There is little information in these studies about rates of other complications, including the impact on quality of life. None of the observational studies we evaluated gave specific rates of other complications for asymptomatic patients. However, among the RCTs, the VACS reported surgical complications rates of 3.8% for cranial nerve injuries (none of these injuries were permanent), 5.2% for hypotension, and 25% for hypertension.^40^

### Is there a population subgroup for which the magnitude of benefits from CEA may be greater than in other subgroups?

Studies reviewed for KQ3 and KQ4 were examined for demographic and co-morbidity subanalyses; the methods of these studies are discussed in more detail below.

#### Age

In ACAS, subjects younger than 68 years old had a RRR from CEA of 0.60 over five years for ipsilateral stroke or perioperative stroke or death (95% CI, 0.11–0.82).^35^ For subjects over 68 years old, there was no significant benefit to CEA at five years (RRR 0.43, -0.07–0.70). Sub-analysis showed that the RRRs were not statistically significantly different by gender. In ACST, subgroup analysis was performed using the outcome: non-perioperative carotid territory strokes.^36^ In the subgroup analysis, patients under age 65 and between 65 and 74 years old showed similar 5-year estimated absolute risk reduction (ARR) for non-perioperative strokes, 7.8% (95% CI: 4.3–11.3) and 7.5% (95% CI: 4.7–10.3), respectively. However, for patients over 74 years old, the number of non-perioperative strokes at five years was not statistically significantly different between the CEA and medical management groups (ARR 3.3, 95% CI: -1.9 – 8.4).

#### Sex

Subgroup analysis in ACAS reported that for ipsilateral stroke or perioperative events, men had a relative risk reduction (RRR) of 0.66 over five years (95% CI, 0.36–0.82) and women had a RRR of 0.17 (-0.96–0.65). In ACST, the subgroup analysis reported a significant benefit to CEA in reducing non-perioperative carotid territory ischemic strokes in men (ARR 8.2%, 95% CI: 5.6–10.8).^36^ In women, there was less but still significant benefit for those randomized to the CEA group (ARR 4.1%, 95% CI: 0.7–7.4). A later subgroup analysis by gender was published in a letter to the editor and used the outcome of stroke or perioperative death at six years. Using their 6-year projections, the absolute difference between CEA and medical groups for stroke or perioperative death was 4.0% (standard error (SE) = 2.2, p = 0.07) for women and 6.6% (SE =1.6, p = 0.0001) for men.^57^ The 30-day rates of perioperative stroke or death in ACAS and ACST were higher in women than men and may explain the sex differences in risk reduction. None of the observational studies directly compared rates of perioperative complications in women with those in men.

#### Race/Ethnicity

The RCTs of CEA versus medical treatment included few people from minority groups. Only one observational study evaluated racial and ethnic variations in CEA perioperative outcomes. Horner, et al compared outcome rates for blacks, Hispanics, and whites.^45^ Perioperative stroke or death rates were 2.1% for blacks, 2.2 for Hispanics, and 1.6% for whites and were not statistically significantly different. For outcomes other than stroke or death, there were some statistically significant differences by race/ethnicity: blacks had a significantly lower rate of any other complications; and blacks and Hispanic patients had a higher rate than whites of return to the operating room due to CEA complications (4.6% for black patients, 7.8% for Hispanics, and 3.6% for white patients).

#### Contralateral Occlusion

Baker, et al used the data from ACAS to evaluate outcomes of CEA by the presence of contralateral occlusion.^39^ He identified 1,648 subjects from ACAS who had a baseline carotid ultrasound, and calculated rates of adverse outcomes for those with and without contralateral occlusion on the baseline ultrasound. Men, whites, and those with a history of TIA or stroke were more likely to have contralateral occlusion. Cumulative 5 year rates of perioperative stroke or death or subsequent ipsilateral stroke for those without contralateral occlusion were 11.7% for the medical group and 5.0% for the surgical group. This translates into a statistically significant absolute risk reduction (ARR) of 6.7% and a RRR of 57%. For the same outcome, subjects with contralateral occlusion had 5 year estimated rates of 3.5% in the medical group and 5.5% in the surgical group for a non-significant increase in risk of 2.0%. Subjects with and without contralateral occlusion had similar rates of perioperative outcomes. Authors, therefore, concluded that subjects with contralateral occlusion did not benefit and may even be harmed from CEA.

#### Comorbidities

In ACST, subgroup analysis was performed using the outcome: non-perioperative carotid territory strokes.^36^ In the subgroup analysis, there was greater risk reduction in non-perioperative strokes in those with higher pre-randomization cholesterol levels: subjects with a cholesterol level less than 250 mg/dL had an ARR of 4.6% at five years, while those with a cholesterol level greater than 250 mg/dL had an ARR of 11.7% at five years. Further subanalyses indicated that the ARR for non-perioperative strokes at five years was not significantly different by pre-randomization blood pressure, degree of carotid stenosis, status of the contralateral carotid artery, diabetes, or CHD.

Only one observational study, Halm, et al, examined CEA outcomes categorized by co-morbidities.^7^ Comorbidities categories were defined using the Revised Cardiac Risk Index. The Revised Cardiac Risk Index uses six risk factors to predict major cardiac complications of surgery: high-risk type of surgery, ischemic heart disease, history of congestive heart failure, history of cerebrovascular disease, insulin therapy for diabetes, and serum creatinine >2.0 mg/dL.^58^ Asymptomatic subjects with no risk factors, one risk factor, and two risk factors had 30-day stroke/death rates of 1.28%, 2.21%, and 2.77%, respectively. Subjects with three or more risk factors or an end-stage disease had a perioperative stroke/death rate of 5.56%.

In summary, subgroup analyses have raised interesting questions for future research about the benefits of CEA for women and for individuals older than 75, without hypercholesterolemia, and with higher levels of co-morbidities. Individuals with contralateral carotid occlusion likely do not benefit from CEA. There are, of course, limitations to the use of subgroup analyses to determine the benefits of CEA, in that the studies under review were not designed to study the subgroups and may not be powered to detect differences between the subgroups. From current evidence, there is no subgroup that we can definitely conclude would benefit from CEA to a much greater degree than others.