# Background

## What is Carotid Artery Stenosis?

Carotid artery stenosis refers to pathologic atherosclerotic narrowing of the extracranial carotid arteries. While one might expect that the amount of narrowing of the carotid artery that constitutes a diagnosis of carotid artery stenosis is correlated to the stroke risk, this relationship has not been clearly demonstrated. The risk is difficult to determine, and consequently CAS is variably defined. More recent RCTs evaluating the benefit of CEA defined CAS as 60–99% (i.e., ACAS, ACST) while earlier RCTs used 50–99%.

## Prevalence and Clinical Importance of Carotid Artery Stenosis in the General Population

The prevalence of carotid artery stenosis has been studied in several population-based cohort and cross-sectional studies. These prevalence estimates are based on a positive test result on a screening carotid ultrasound, a test with limited reliability and accuracy. Estimates of the prevalence of CAS from population-based studies range from 0.5% to 8%.^8^–^12^ Based on the population-based studies and the accuracy of ultrasound, we estimate the actual prevalence of clinically important CAS (60%–99%) in the general primary care population to be approximately 1% or less; in those aged 65 years and older we estimate prevalence to be about 1%. See below in the Results section for a more detailed discussion of prevalence.

A “clinically important degree of CAS” is defined as the percentage of stenosis that corresponds to a substantially increased risk of stroke. Stroke risk depends on more than the degree of carotid artery narrowing; it is therefore difficult to define categories of CAS that are associated with various risk levels of stroke in asymptomatic people. Another difficulty is that all prospective studies of stroke risk have measured CAS by carotid ultrasound, an imperfect “gold standard.” In the population-based Cardiovascular Health Study of people ages 65 years and older, the risk of stroke rose as severity of stenosis increased above 50%, declining at the very highest degrees of CAS (probably due to collateral circulation). The estimated 5-year risk of ipsilateral stroke for asymptomatic people with CAS ≥ 50% was approximately 4% and for CAS ≥ 70% approximately 8%.^10^ Other studies have also shown an increased risk with greater degrees of stenosis and with multiple risk factors.^13,^ ^14^ Most studies of treatment for CAS consider stenosis ≥ 50% or ≥ 60% as clinically important.

## CAS-Related Stroke Burden

The contribution of CAS to overall stroke burden is difficult to approximate. Approximately 88% of strokes are ischemic; 20% or less of these are due to “large artery stenosis”.^10,^ ^15^–^20^ A subgroup of this “large artery stenosis” category is due to stenosis of the carotid bifurcation or proximal carotid artery that is approachable by CEA and a proportion of patients in this subgroup are asymptomatic. A recent follow-up study of people in a large RCT of carotid endarterectomy found that approximately 45% of strokes among asymptomatic people with severe carotid artery stenosis were unrelated to the carotid artery stenosis and could not have been prevented by CEA.^21^ Thus, screening asymptomatic people for CAS to perform CEA would potentially have an effect on 10% or fewer of all strokes. Because of the large number of strokes each year, this constitutes a considerable health burden.

## Risk Factors for Carotid Artery Stenosis

There is much literature on the risk factors for developing CAS; however, there are few studies that associate risk factors with a clinically important degree of stenosis, such as ≥ 60 %. This literature relies on ultrasound measurement of CAS, which again includes some misclassification.

Important risk factors or combinations thereof for clinically significant CAS are age > 65 years, male sex, smoking, heart disease, and hypertension.^9,^ ^22^–^27^ The presence of the strongest reported risk factors, smoking or heart disease, approximately doubles the risk of CAS. ^25,^ ^26^ However, no single risk factor and no clinically-useful risk model incorporating multiple factors, clearly discriminates people who have clinically important CAS from people who do not.