# Appendix 4. Evidence Table on Complications Rates for Carotid Endarterectomy

Part I of Evidence Table

| | | Total Population
| Design
| Setting
Study Reference | Source population | Population Selection | N | Characteristics
Bratzler 1996 ^47^ | Retrospective, observational study using Medicare claims database and medical records | 1993-1994 | 813 CEAs | Median-73 yrs
| 8 hospitals in Oklahoma (OK) | All CEA cases from the OK Medicare claims data; hospital selection not specified; all surgeons performing CEA in the 8 study hospitals | (774 patients) | % White NR
| OK Medicare beneficiaries | | | % Female NR
| | | | 26% DM
| | | | 20% COPD
| | | | 10% CHF
| | | | 67% CHD
| | | | 71% HTN
| | | | 26% Smoke
| | | | 98% had stenosis
| | | | > 60%
Cebul 1998 ^48^ | Retrospective, cohort study using Medicare provider analysis and review files | 7/93 – 6/94 | 678 patients | Mean-73.1 yrs
| 115 hospitals/478 surgeons in Ohio (OH) | Random sample of 700 of 4,120 non-HMO Medicare beneficiaries in OH (18 patients had no medical record; 4 had stroke; 3 had bilateral carotid procedures during same hospitalization); hospitals performing CEA in OH | | 94% White
| | | | 46% Female
| | | | 26% DM
| | | | 16% COPD
| | | | 9% CHF
| | | | % CHD NR
| | | | 71% HTN
| | | | 31%^1^ Smoke
| | | | % stenosis NR
Halm 2003 ^7^ | Cross-sectional study based on medical record review of in- and outpatient records | 1/97 – 12/98 | 2124 | Mean-72 yrs
Rockman 2005 ^55^ | 4 university hospitals, 2 community hospitals served by 67 surgeons | Reviewed 2,365 of 2,390 CEAs based on hospitals' databases. Cases excluded if re-operation, surgery combined with other major procedure, no CEA performed or missing data. | | 87% White
Halm 2005 ^53^ | | Each hospital contributed 130–583 cases. | | 43% Female
Press 2006 ^54^ | | | | 29% DM
| | | | 9% COPD
| | | | 8% CHF
| | | | % CHD NR
| | | | 73% HTN
| | | | % Smoke NR
| | | | 96% had > 50% stenosis
Halm 2007 ^49^ | Retrospective, observational study using New York State Medicare claims database and medical records | 1/98 – 6/99 | 9588 | Mean - 74.6 yrs
| | Reviewed 10, 817 eligible cases (94.8%). Excluded reoperations, CEA combined with CABG, or no CEA performed. 551 cases excluded because of missing data. | | 93% White
| | | | 56% Male
| | | | 30% DM
| | | | 19% COPD
| | | | 10% CHF
| | | | 62% CHD
VA - NSQIP | Secondary analysis of VA NSQIP data | 1994-1995 | 7,842 | Mean-68 yrs
Samsa 2002 ^46^ | 132 VA medical centers | 1996-1997 | | 91% White
| Patients undergoing surgery at a VA medical center | 94% of those available for assessment included in database, most excluded because of multiple index operations; 5 of the 123 VAs assessed < 80% of eligible cases. | | 2% Female
| | All VA hospitals performing major surgery; all surgeons performing surgery at VA hospitals. | | 17% DM
| | | | 17% COPD
| | | | 2% CHF
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | % Stenosis NR
Horner 2002 ^45^ | Secondary analysis of data in VA NSQIP examining differences in CEA outcomes by ethnic group | 10/94 – 9/97 | 6551 | 20% ≥ 75 yrs
| 132 VA Medical Centers | Limited to men having CEA | | 91% White
| Patients having CEA | | | 0% Female
| | | | 29% DM
| | | | 12% COPD
| | | | 2% CHF
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | % Stenosis NR
Karp 1998 ^50^ | Retrospective, cross- sectional study | 1993 | 1945 | Mean-72.3 yrs
| Medicare beneficiaries who underwent CEA in Georgia | Excluded 35 cases due to missing data. | | 91% White
| | | | 47% Female
| | | | 22% DM
| | | | 24% COPD
| | | | 8% CHF
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | 69% > 75%
Kresowik 2000 ^52^ | Retrospective, observational study using Medicare database and medical records | 1994 & 6/95 to 5/96 | 2063 | Median-74 yrs
| 30 hospitals in Iowa | All CEA cases from the Iowa Medicare claims database (Part A & B); all hospitals in Iowa performing CEA on Medicare patients; all surgeons in Iowa performing CEA on Medicare patients | | % White NR
| Iowa Medicare beneficiaries | | | 40% Female
| | | | % DM NR
| | | | % COPD NR
| | | | % CHF NR
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | % Stenosis NR
Kresowik 2001 ^51^ | Retrospective, observational study using Medicare database and medical records | 6/95 – 5/96 | 10,030 patients | Mean-73.6 yrs
| 10 states | Random sample of 10,561 from 28,083 procedures identified from the MEDPAR Part A claims. | | % White NR
| Medicare beneficiaries | | | 43% Female
| | | | % DM NR
| | | | % COPD NR
| | | | % CHF NR
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | % Stenosis NR
Kresowik 2004 ^44^ | Retrospective, observational study using Medicare database and medical records | 6/98 – 5/99 | 9,945 patients | Mean-NR
| 10 states | Random sample of procedures identified from the MEDPAR Part A claims. | | % White NR
| Medicare beneficiaries | | | 43% Female
| | | | % DM NR
| | | | % COPD NR
| | | | % CHF NR
| | | | % CHD NR
| | | | % HTN NR
| | | | % Smoke NR
| | | | % Stenosis NR

Percentages have been rounded.

1 Past or present smoker; NR = Not Reported, CEA = carotid endarterectomy DM = diabetes mellitus, COPD = chronic obstructive pulmonary disease, CHF = congestive heart failure, CHD = coronary heart disease, HTN = hypertension, CVA = stroke, MI = myocardial infarction, HMO = health maintenance organization, VA = Veterans affairs, NSQIP = National VA Surgical Quality Improvement Program, CVA = cerebral vascular accident, CABG = coronary artery bypass graft, ESRD = end stage renal disease, OR = odds ratio, MI = myocardial infarction, MEDPAR = Medicare Provider Analysis and Review

Part II of Evidence Table

| Total Asymptomatic Population
| | | Outcomes
| | | 30-day Stroke/Death | Threats to
| N | | Other Complications | Internal Validity
Study Reference | (% Total) | Characteristics | (Asymptomatic) | External Validity | Quality Rating
Bratzler 1996 ^47^ | 347 | Not reported | Overall = 3.7% | Data collected from medical record and claims database | Good
| (43%) | | High volume hospital (>100 cases/year) = 3.5% | Reviewer blinding not discussed
| | | Low volume hospital = 5.2% | No comprehensive evaluation, outcomes determined by coding or documentation in chart
| | | 3% HTN | Generalizability low, select population
| | | 2% wound hematoma
| | | 2% pneumonia
Cebul 1998 ^48^ | 167 | Not reported | 2.4% | No assessment of patients, outcomes determined from readmission data; study did not include outpatient visits | Fair
| (25%) | | Hospital-specific stroke/death rates inversely related to the number of procedures, ranging from 7.7% lowest quartile to 2.5% highest quartile | Predominantly white population
| | | Asymptomatic patients at higher-volume hospitals (greater than median) had no strokes or death at 30 days compared to 4.9% and 4.6% in lower volume hospitals. Outcomes did not differ significantly by surgeon volume.
| | | Undergoing surgery in a higher volume hospital was associated with a 71% reduction in risk of stroke or death at 30 days, after adjusting for patient characteristics (OR=0.29 (0.12–0.69)).
Halm 2003 ^7^ | 1413 | Not reported | Asymptomatic with no co-morbidities = 1.28% | Complication rates (especially CVA) are underestimated by administrative database. | Good
Rockman 2005 ^55^ | (65%) | | Low comorbidity (1 cardiac risk factor) = 2.21% | No assessment of patients by neurologist
Halm 2005 ^53^ | | | Moderate (2) = 2.77% | All hospitals in 1 region, may not be generalizable.
Press 2006 ^54^ | | | High (ESRD, severe disability or over 2 risk factors) = 5.56%
| | | Mean complication rate across groups = 2.6%
Halm 2007 ^49^ | 72% | Not reported | Asymptomatic without high comorbidity = 2.69% | Large number of cases excluded due to missing data. | Fair
| | | Asymptomatic with high comorbidity = 7.13% | Complication rates (especially CVA) are underestimated by administrative database.
| | | | No assessment of patients by neurologist
| | | | All hospitals in 1 region, may not be generalizable.
VA - NSQIP | 3,231 | not reported | 30-day death, CVA, MI | Reviewer not blinded to treatment, hospital course | Good
Samsa 2002 ^46^ | | | Overall = 2.4% | Loss to follow-up not discussed, although likely very little
| | | 1994-95 = 2.7% | No comprehensive exam by neurologist for outcome assessment
| | | 1996-97 = 2.2% | No discussion of hospital selection
| | | | Other complications not listed
| | | | Generalizability low select population (white males)
Horner 2002 ^45^ | 2852 | 20% ≥ 75 yrs | Stroke or death: | Little selection within VA (VA patients are a selected subgroups of US population) | Good
| (44%) | 92% White | 1.6% white
| | 0% Female | 2.1% black
| | 28% DM | 2.2% Hispanic
| | 10% COPD | Stroke, MI or death
| | 2% CHF | 2.3% white
| | % CHD NR | 2.1% black
| | % HTN NR | 3.2% Hispanic
| | % Smoke NR
| | % Stenosis NR
Karp 1998 ^50^ | 972 | Not reported | Mortality=0.8% | No comprehensive exam by neurologist for outcome assessment | Fair
| (51%) | | Mod/Severe Stroke =1.0% | No discussion of hospital selection
| | | MI = 0.8% | Generalizability low (all males, mostly white)
| | | Combined (above) = 2.6%
| | | All Stroke = 2.4%
| | | Symptomatic patients:
| | | Mortality = 1.7%
| | | Mod/Severe Stroke = 2.7%
| | | MI = 1.4%
| | | Combined (above) = 5.8%
| | | All stroke = 4.7%
| | | Found statistically significant increase in morbidity, mortality and less severe complications at hospitals performing ≤10 CEAs.
Kresowik 2000 ^52^ | 671 | Not reported | Overall = 3.4% | Unclear when reports of outcomes were given to hospitals & surgeons. | Good
| (20% '94; 40% '95–96) | | 1994 = 3.8% | No comprehensive evaluation, depended on medical records for outcomes.
| | | 1995-96 = 3.3% | Relied on claims database for readmissions for stoke, death occurring after discharge.
| | | | Generalizability
Kresowik 2001^51^ | 3120 | Not reported | Combined events 3.7% | Missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization. | Good
| (39%) | | Mortality 1.1%
| | | The combined event rate by state for asymptomatic patients ranged from 2.3% to 6.7%. Mortality ranged from 0.5% to 2.5%. Only 2 states significantly different from the mean.
Kresowik 2004^44^ | 4093 | Not reported | Combined events 3.8% | Missed nonfatal neurologic events occurring after discharge that did not result in another hospitalization. | Good
| | | The combined event rate by state for asymptomatic patients ranged from 1.4% to 6.0%. Only 3 states significantly different from the mean.

Percentages have been rounded.

1 Past or present smoker;

NR = Not Reported, CEA = carotid endarterectomy DM = diabetes mellitus, COPD = chronic obstructive pulmonary disease, CHF = congestive heart failure, CHD = coronary heart disease, HTN = hypertension, CVA = stroke, MI = myocardial infarction, HMO = health maintenance organization, VA = Veterans affairs, NSQIP = National VA Surgical Quality Improvement Program, CVA = cerebral vascular accident, CABG = coronary artery bypass graft, ESRD = end stage renal disease, OR = odds ratio, MI = myocardial infarction, MEDPAR = Medicare Provider Analysis and Review