# Appendix 3. Evidence Table for Randomized Controlled Trials for Effectiveness of Surgery versus Medical Management for Asymptomatic Carotid Artery Stenosis

Part I of Evidence Table

Study | Sample Size & Intervention Groups | Demographics/Comorbidities | | Source of Patients | Prerandomization Evaluation & Required Stenosis | Required Preoperative A-gram?
| | | | | | A-gram Complic. Rate
WRAMC ^29^ | Total = 29 | Mean age = 63 years | | Not reported | OPG | Yes
| ASA = 14 | Male | 72%
| CEA = 15 | HTN | 69%
| | DM | 14%
| | ↑Chol | 10%
| | Smoke | 72%
MACE ^30^ | Total = 71 | 70% > 65 years | | Not reported | OPG, U/S, or angiogram | Yes
| ASA = 35 | Male | 56–60%
| CEA = 36 | White
| | HTN | 63%
| | DM | 14–19%
| | ↑Chol | 44–66%
| | Smoke | 67–74%
VACS ^31^ | Total = 444 | Mean age 65 years | | Not reported | A-gram | Yes
| MM = 233 | Male | 100% | | ≥ 50% | 0.4%
| CEA = 211 | White | 86–88%
| | HTN | 63–64%
| | DM | 27–30%
| | ↑Chol | NR
| | Smoke | 49–52%
| | Contralateral TIA/stroke = 32%
ACAS ^32^ | Total = 1659 | Mean age = 67 years | | Vascular ultrasonography laboratories, physicians who found bruits during evaluation for PVD or contralateral CEA | U/S or angiogram | Yes
| MM = 834 | Male | 66% | | ≥ 60% | 1.2%
| CEA = 825 | White | 94–95%
| | HTN | 64%
| | DM | 23%
| | CAD | 69%
| | ↑Chol | % NR
| | Smoke | 26%
| | Contralateral CEA= 20%
ACST ^33^ | Total = 3,120 | Mean age = 68 years | | Medical and surgical clinics | U/S | No
| MM = 1,560 | Male | 66% | | ≥ 60%
| CEA = 1,560 | HTN | 65%
| | DM | 20%
| | ↑Chol | 73%
| | Smoke | NR
| | Non-DM CAD | 27%
| | Contralateral CEA 24%

§ Five-year non-perioperative stroke;

† Not statistically significantly different;

◊ Statistically significantly different;

‡ No significant benefit to CEA in this group;

∞ Statistical significance between groups not reported

WRAMC = Walter Reed Army Medical Center Study; MACE = Mayo Asymptomatic Carotid Endarterectomy Study; VACS = Veterans Affairs Cooperative Study; ACAS = Asymptomatic Carotid Atherosclerosis Study; ACST = Asymptomatic Carotid Surgery Trial; NR=Not reported, MM = Medical Management; ASA = aspirin; CEA = carotid endarterectomy group; HTN = hypertension; DM = diabetes mellitus; ↑Chol = hyperlipidemia; CAD = coronary artery disease; TIA = transient ischemic attack; OPG = ocular pneumoplethysmography; U/S = ultrasound; PVD = peripheral vascular disease; MI = myocardial infarction; CI = confidence interval; RR = relative risk; ARR = absolute risk reduction; RRR = relative risk reduction; SE = standard error; W = women; M = men

Part II of Evidence Table

Study | Mean Follow-up Time | 30-day Complic. Rate of CEA : Stroke/Death, MI | | Results: any CVA & Perioper. Stroke/death (95% CI) | Rate of Perioperative CVA/Death & Subseq. Ipsilat. Stroke (95% CI) | Quality Rating
WRAMC ^29^ | 3 years | Not reported | | ASA = 0/15 | Not reported | Poor
| | | | CEA = 3/15
MACE ^30^ | 23.6 months | Stroke/death: | 4% | ASA = 0% | Not reported | Poor
| | MI: | 8% | CEA = 8.3%
VACS ^31^ | 48 months | Stroke/death: | 4.7% | Five-year incidence of death or stroke: | Not reported | Fair
| | MI: | 1.9% | MM: 44.2%†
| | | | CEA: 41.2%
| | | | RR 0.92
| | | | (0.69–1.22)
ACAS ^32^ | 2.7 years | Stroke/death: | 2.7% | RRR = 20% | Five Year:◊ | Good
| | MI: | NR% | (-2–37%) | MM = 11%
| | [underlined: Sex]:† | | | CEA = 5.1%
| | Women: | 3.6% | | RRR = 53%
| | Men: | 1.7% | | ARR = 5.9%
| | | | | [underlined: Sex]:†
| | | | | W: RRR 0.17‡
| | | | | (-0.96–0.65)
| | | | | M: RRR 0.66
| | | | | (0.36–0.82)
| | | | | [underlined: Age]: †
| | | | | < 68: RRR 0.60
| | | | | (0.11–0.82)
| | | | | ≥ 68: RRR 0.43 ‡
| | | | | (-0.07–0.70)
ACST ^33^ | 3.4 years | stroke/death: | 2.8% | Five year: ◊ | Not reported | Good
| | MI: | 0.6% | MM = 11.8%
| | [underlined: Sex]: ∞ | | CEA = 6.4%
| | W: | 3.1% | ARR = 5.4%
| | M: | 2.2% | RRR = 46%
| | [underlined: Age]: ∞ | | [underlined: Sex:] § ∞
| | < 65: | 2.4% | W: ARR = 4.1%
| | 65–74: | 2.3% | M: ARR= 8.2%
| | > 75: | 3.3% | [underlined: Age]: § ∞
| | | | < 65: ARR 7.8%
| | | | 65–74: ARR 7.5%
| | | | ≥ 75: ARR 3.3%‡

§ Five-year non-perioperative stroke;

† Not statistically significantly different;

◊ Statistically significantly different;

‡ No significant benefit to CEA in this group;

∞ Statistical significance between groups not reported

WRAMC = Walter Reed Army Medical Center Study; MACE = Mayo Asymptomatic Carotid Endarterectomy Study; VACS = Veterans Affairs Cooperative Study; ACAS = Asymptomatic Carotid Atherosclerosis Study; ACST = Asymptomatic Carotid Surgery Trial; NR=Not reported, MM = Medical Management; ASA = aspirin; CEA = carotid endarterectomy group; HTN = hypertension; DM = diabetes mellitus; ↑Chol = hyperlipidemia; CAD = coronary artery disease; TIA = transient ischemic attack; OPG = ocular pneumoplethysmography; U/S = ultrasound; PVD = peripheral vascular disease; MI = myocardial infarction; CI = confidence interval; RR = relative risk; ARR = absolute risk reduction; RRR = relative risk reduction; SE = standard error; W = women; M = men