# Appendix 2. USPSTF Hierarchy of Research Design and Quality Rating Criteria^1,^ ^2^

HIERARCHY OF RESEARCH DESIGN

- I Properly conducted randomized controlled trial (RCT)
- II-1: Well-designed controlled trial without randomization
- II-2: Well-designed cohort or case-control analytic study
- II-3: Multiple time series with or without the intervention; dramatic results from uncontrolled experiments
- III: Opinions of respected authorities, based on clinical experience; descriptive studies or case reports; reports of expert committees

DESIGN-SPECIFIC CRITERIA AND QUALITY CATEGORY DEFINITIONS

[underlined: Systematic Reviews]

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance are especially important for systematic reviews

Definition of ratings from above criteria:

- Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions.
- Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies.
- Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies.

[underlined: Case-Control Studies]

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on criteria above:

- Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equally to or greater than 80 percent; diagnostic procedures and measurements accurate and applied equally to cases and controls; and appropriate attention to confounding variables.
- Fair: Recent, relevant, without major apparent selection or diagnostic work-up bias but with response rates less than 80 percent or attention to some but not all important confounding variables.
- Poor: Major section or diagnostic work-up biases, response rates less than 50 percent, or inattention to confounding variables.

[underlined: Randomized Controlled Trials and Cohort Studies]

Criteria:

- Initial assembly of comparable groups
  - -for RCTs: adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  - -for cohort studies: consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to follow-up or overall high loss to follow-up
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of the interventions
- All important outcomes considered

Definition of ratings based on above criteria:

- Good: Evaluates relevant available screening tests; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100 broad-spectrum of patients.
- Fair: Evaluates relevant available screening tests; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
- Poor: Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum of patients.

[underlined: Diagnostic Accuracy Studies]

Criteria:

- Screening test relevant, available for primary care, adequately described
- Study uses a credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Handles indeterminate result in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Administration of reliable screening test

Definition of ratings based on above criteria:

- Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; reliability of test assessed; has few or handles indeterminate results in a reasonable manner; includes large number (more than 100) broad-spectrum patients with and without disease.
- Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; moderate sample size (50–100 subjects) and a “medium” spectrum of patients.
- Poor: Has fatal flaw such as: Uses inappropriate reference standard; screening test improperly administered; biased ascertainment of reference standard; very small sample size or very narrow selected spectrum patients.

## References

1 Harris R, Atkins D, Berg AO, Best D, Eden KB, Feightner JW et al. US Preventive Services Task Force Procedure Manual. Rockville, MD: Agency for Healthcare Research and Quality, 2001.
2 Harris RP, Helfand M, Woolf SH, Lohr KN, Mulrow CD, Teutsch SM, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].