# Appendix 1. Literature Search and Inclusion/exclusion Criteria for Key Questions

Key Question 4. CEA complication rates

[underlined: Literature Search]

1. endarterectomy, carotid [mesh] AND outcome and process assessment (health care) [mesh]. Yield = 690.

Limited to “usa [ad]”, which picks up the country designation USA in the author affiliation/address field. This yielded 209 items.

2. Related article search through PubMed

Related articles to: Feasby, Hospital and surgeon determinants of carotid endarterectomy outcomes. Arch Neurol. 2002 Dec; 59(12):1877–81. Yield = 27 studies.

[underlined: Inclusion/Exclusion Criteria for Complication Rates of CEA]

Inclusion

Studies that include complication rates related to CEA by 30 day mortality or stroke for asymptomatic patients

Studies that evaluate differences in outcomes by technique, including:

- Different types of patches
- Shunting
- Eversion techniques

Studies that evaluate differences in outcomes by surgical specialty, including:

- Neurosurgeon
- Vascular surgeon
- General surgeon

Studies that evaluate differences in outcomes by non-surgical factors:

- Anesthesia type
- Intraoperative ultrasound or other imaging
- Intraoperative angiography

Studies that evaluate differences in outcomes by patient factors:

- Age
- Gender
- Race

Studies that include more than one surgeon and more than one hospital

Studies evaluating complication differences by surgical specialty, training, or experience

Studies evaluating complication differences by surgeon or hospital volume and by setting

Studies that have complication rates for asymptomatic patients

Case series, RCTs, meta-analysis

Exclusion

Studies evaluating only patients with combined CEA and coronary artery bypass graft

Studies that include only patients receiving stenting, angioplasty, endovascular treatment

Studies that include only symptomatic patients or don't separate rates by symptom status

Non-United States studies

Review articles without outcome data

Studies that include only patients with prior stroke

Studies evaluating re-stenosis outcomes only

Recurrent stenosis studies

Quality improvement studies without complication rates listed

Utilization studies without complication rates

Pseudoaneurysm studies

Bilateral CEA studies

Emergent CEA studies

Studies including outcomes for only one surgeon or only one clinical site

Studies with < 50 subjects

Not on harms of CEA

No relevant or 30 day outcomes

High risk or special populations

Incorrect study type

Inclusion/Exclusion Criteria for Key Questions 1–3

Key Question 1. Benefits of screening

Randomized Controlled Trial (RCT)

Compared screened versus non-screened groups

Outcomes of strokes or death

Outcomes specific for asymptomatic subjects

Population generalizable to U.S.

Published in English

Key Question 2. Accuracy and reliability of screening

Ultrasound, MRA, or computed tomography screening

Asymptomatic subjects

Systematic reviews of studies that compared screening test to gold standard of angiography

Population-based prevalence studies

Population generalizable to U.S.

Published in English

Key Question 3. Benefits of CEA

RCTs of CEA comparing surgical treatment to medical treatment

Reported 30-day complication rates of CEA

Outcomes of stroke and/or death

Outcomes specific for asymptomatic subjects

Population generalizable to U.S.

Published in English